# Contributors

Ann Abramowitz, Ph.D.

Emory University

Atlanta, GA

Anne Chelminski, M.D., M.P.H.

University of North Carolina

Chapel Hill, NC

Lisa Clements, Ph.D.

Missouri HealthNet

Missouri Department of Social Services

Jefferson City, MO

Tammy Davis, Ed.D.

American School Counselor Association

Alexandria, VA

Tiffany Farchione, M.D.

U.S. Food and Drug Administration

Division of Psychiatry Products

Silver Spring, MD

Stephen Faraone, M.D.

Upstate Medical University

State University of New York

Syracuse, NY

Laurence Greenhill, M.D.

New York State Psychiatric Institute

New York, NY

Penelope Knapp, M.D.

M.I.N.D. Institute

University of California Davis

Sacramento, CA

Sarah Mulligan, M.Ed.

Division for Early Childhood, Council for Exceptional Children

Missoula, MT

Sue Visser, Ph.D.

Centers for Disease Control and Prevention

National Center for Birth Defects and Developmental Disabilities

Atlanta, GA

Benedetto Vitiello, M.D.

National Institute of Mental Health

National Institutes of Health

Rockville, MD

Julie Zito, Ph.D.

University of Maryland, Baltimore

Baltimore, MD