# Executive Summary

## Background

This Future Research Needs (FRN) report is based on a draft Agency for Healthcare Research and Quality Comparative Effectiveness Review, Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-Risk Preschoolers; Long-Term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment.

The Key Questions (KQs) were:

- KQ 1: Among children less than 6 years of age with attention deficit hyperactivity disorder or disruptive behavior disorder, what are the effectiveness and adverse event outcomes following treatment?
- KQ 2: Among people age 6 years or older with attention deficit hyperactivity disorder, what are the effectiveness and adverse event outcomes following 12 months or more of any combination of followup or treatment, including, but not limited to, 12 months or more of continuous treatment?
- KQ 3: How do (a) underlying prevalence of ADHD, and (b) rates of diagnosis (clinical identification) and treatment for ADHD vary by geography, time period, provider type, and sociodemographic characteristics?

Findings in the draft review for KQ 1 supported the use of parent behavior training in preschoolers both for oppositional behaviors and for attention deficit hyperactivity disorder (ADHD) symptoms, with no adverse events reported. For preschoolers, psychostimulant medications are also generally safe and efficacious for improving behavior and can provide benefits in addition to parent training. However, adverse events, especially irritability and moodiness, can lead to discontinuation, and use for several months to a year slightly affects growth rate.

For KQ 2, long-term effectiveness and safety studies of several psychostimulants in children older than 6 years old and adolescents found they are efficacious for control of inattention and overactivity for extended periods of time. Few serious adverse events were noted. Publications from the Multimodal Treatment Study of Children with Attention Deficit Hyperactivity Disorder (MTA) study provide the best data for long-term outcomes. By 3 years, no single intervention group showed superior benefit, which is likely because of individuals obtaining a complex range of interventions in the community.

The findings for KQ 3 included results from a systematic review and meta-regression that estimated the prevalence of ADHD among those ages 18 or younger at 5.29 percent, with more boys than girls identified and the highest rates of disorder occurring in 5- to 10-year-olds. Primary sources of variability were identified as methodological rather than geographic. Fewer studies are available that document prevalence in adult, adolescent, or preschool age groups.

In the draft review there was little or no evidence to draw conclusions for several questions. We developed the list of evidence gaps in Table A based on information from the draft review and input from the stakeholder panel. We developed an analytic framework to show the relationships between the evidence gaps, populations, interventions, comparators, outcomes, timeframes, and settings (PICOTS), and Key Questions (Figure A).

Table A Preliminary evidence gaps by Key Question

Evidence Gap | Relevant Key Question
For children less than 6 years old with disruptive behavior disorder or ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs (e.g., parent training and summer behavior treatment programs), alone or in combination with pharmacological interventions, compared with other psychosocial treatment programs, alone or in combination with pharmacological interventions. | KQ 1
For children less than 6 years old with disruptive behavior disorder or ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs alone compared with pharmacological treatments, alone or in combination with psychosocial treatments. | KQ 1
Among children less than 6 years old with disruptive behavior disorder or ADHD, there is a paucity of research examining positive child treatment results for variants on multimodal interventions (e.g., combinations of parent behavior training, summer behavior treatment programs, school-based interventions, or other cross-sector evaluations), alone or in combination with pharmacological interventions, and effects on specific subgroups. | KQ 1
For preschoolers with disruptive behavior disorder or ADHD, there are few efficacy and effectiveness studies on prescriptive treatments or optimal circumstances for adding specific psychosocial and/or pharmacological treatment components based on the child’s needs. | KQ 1
Among people less than 6 years old with disruptive behavior disorder or ADHD, there is a lack of high-quality studies on efficacy and effectiveness of biofeedback and working memory training. | KQ 1
Among children ageless than 6 years with disruptive behavior disorder or ADHD, there is a paucity of studies documenting adverse events or noncompliance rates for psychosocial interventions including parent training and school-based interventions. | KQ 1
For children less than 6 years of age with ADHD, limited data are available on the influence of parental preferences regarding treatment approaches or modes of service delivery on short- and long-term outcomes. | KQ 1
Among children less than 6 years old with disruptive behavior disorder or ADHD, there is a paucity of studies that disassemble the key components of available psychosocial treatment programs (e.g., specific parent training techniques compared to treatment components targeting the child and variants in service delivery to accommodate parental preferences). | KQ 1
Conflicting results from treatment studies of children less than 6 years old with disruptive behavior disorder or ADHD show improvements in ADHD symptoms when the parent behavior training protocol is flexible and when the protocol is not flexible. Among children less than 6 years old with disruptive behavior disorder or ADHD, studies comparing the relative efficacy of flexible versus nonflexible parent behavior training protocols are not available. | KQ 1
Limited data are available from studies with appropriate comparison groups about long-term outcomes for preschool interventions. | KQ 1
Among children less than 6 years old with ADHD, there is a paucity of prospective studies that compare the efficacy, effectiveness, and harms of single and/or combination pharmacotherapies with other single or combined pharmacotherapies (e.g., stimulants vs. nonstimulants).^*^ | KQ 1
For children age 6 years or older with ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs (e.g., parent training and summer behavior treatment programs), alone or in combination with pharmacological interventions, compared with other psychosocial treatment programs, alone or in combination with pharmacological interventions. | KQ 2
For children age 6 years or older with ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs alone compared with pharmacological treatments, alone or in combination with psychosocial treatments. | KQ 2
Among children age 6 years or older with ADHD, there is a paucity of research examining positive treatment results for variants on multimodal interventions (e.g., combinations of parent behavior training, summer behavior treatment programs, school-based intervention) alone or in combination with pharmacological interventions, and effects on specific subgroups. | KQ 2
For people age 6 years or older with ADHD, few efficacy and effectiveness studies are available on prescriptive treatments or optimal circumstances for adding specific psychosocial and/or pharmacological treatment components based on the person’s needs. | KQ 2
Among people age 6 years or older with ADHD, there is a lack of high-quality studies on efficacy and effectiveness of biofeedback and working memory training. | KQ 2
Among individuals age 6 years or older with ADHD, there is a paucity of studies documenting adverse events or noncompliance rates for psychosocial interventions including parent training and school-based interventions. | KQ 2
For people age 6 years or older with ADHD, limited data are available examining longer term follow-up of psychosocial and pharmacological ADHD treatments with appropriate comparison groups for long-term outcomes including academic and educational outcomes. | KQ 2
Among people age 6 years or older with ADHD, there is a paucity of prospective combination pharmacological studies (e.g., combination pharmacotherapy treatment) as well as studies that follow individuals no longer requiring medication. | KQ 2
For people age 6 years or older, there is a lack of evidence to support standardized methods for improving adherence to ADHD medications.^*^ | KQ 2
Among people age 6 years or older with ADHD, there is a paucity of studies that examine mediators and moderators of positive treatment response. The extant literature provides limited information about variations in treatment response by specific sociodemographic characteristics (e.g., low socioeconomic status, gender, different racial or ethnic groups) and baseline clinical indices (e.g., comorbidity with other psychiatric disorders, ADHD subtypes, comorbid developmental disorders, comorbid learning disabilities, language impairments, reading or mathematics disorders). | KQ 2
For people age 6 years and older with ADHD, standardized outcome measures such as global impairment scales, quality of life scales, and measures that capture school performance learning capacity, social and emotional functioning, social competence, and functional capacity are needed to compare study outcomes from different cohorts. | KQ 2
Research among people with ADHD age 6 years and older that compares efficacy as measured by different data-capturing methods such as child self-rating scales, parent rating scales, and semistructured interviews is limited. | KQ 2
Research is limited on the direct and relative effects of discrepancies among multiple informants (e.g., parents, children, teachers, clinicians) on the diagnosis of ADHD and the effectiveness of treatments for people of all ages with ADHD. | KQ 2, 3
The extant literature lacks evidence-based measures for assessing prevalence and treatment outcomes for people of all ages with ADHD on a comparable metric. Standardized methods of data collection, case identification, and outcomes measurement in epidemiologic surveys and administrative databases are lacking, particularly for adolescents and adults. | KQ 3
There is a paucity of evidence examining the amount of variation in case identification and prevalence across geographic areas, age groups, settings, and cultures, as well as a lack of research examining the causes and consequences of such variation in children’s access to treatment and outcomes. | KQ 3
Diagnostic tools and measurements for outcomes beyond behaviors associated with ADHD (such as social functioning/interaction with peers) are not standardized. This gap includes a need for brief instruments that can be used in generalizable practice settings including epidemiologically valid long-term cohort studies and practice-based research networks.^*^ | KQ 3
Little research is available that addresses the etiology and consequences of geographic variation in treatment patterns of ADHD in all age groups in terms of effect on outcomes. These factors might include cross-sector coordination of health services, family and child factors, provider factors, and availability and type of insurance. | KQ 3
For people of all ages with ADHD, there is a paucity of comparative evidence from practice-based research regarding access to and the use of generalists in combination with specialists compared with referral to specialists in generalizable practice.^*^ | KQ 3

ADHD = attention deficit hyperactivity disorder; KQ = Key Question

* Evidence gaps were added by the stakeholders during and after the first conference call.

Figure A Analytic framework depicting relationships between Key Questions, populations, interventions, outcomes, and components of evidence gaps

ADHD = attention deficit hyperactivity disorder; KQ = Key Question; SES = socioeconomic status

To the left of center in the figure, a box represents the populations addressed by key questions 1, 2, and 3. These are children less than 6 years of age with disruptive behavior disorder (including Attention Deficit Hyperactivity Disorder (ADHD)) and children 6 years or older, adolescents, and adults with ADHD. Above this box, KQ1, KQ2, and KQ3 are listed to show the relationships between the populations and key questions. Dashed lines with arrows pointing toward the box connect this box to four circles located to the left and above the box. The borders of the circles are dashed lines. The text within the circles describes population characteristics that might influence responses to treatment and methods needed to assess prevalence and treatment outcomes. In the first circle, the text reads, “Sociodemographic Characteristics: Sex, Race/Ethnicity, SES.” In the second circle, the text is, “Psychiatric comorbidity.” In the third circle, the text is. “Comorbid developmental, learning disorders or other disabilities.” And, in the fourth circle the text reads, “Evidence-based performance measures; standardized methods of data collection, case identification, and outcomes measurement.” A thick solid line with an arrow leads to the right from the box representing the populations. This line represents the interventions of interest in the comparative effectiveness review. The interventions are listed as bullet points under the line. These are: pharmacologic, behavioral, and combination pharmacologic and behavioral interventions. Above the line, KQ1, KQ2, and KQ3 are listed to indicate the association between the key questions, interventions, and outcomes of interest. Below the bulleted list of interventions is a circle with a dashed line border. A dashed line with an arrow leads from the circle to the list of interventions. Within the circle is a list of intervention variations. This list is: Prescriptive Treatments; Dismantling Studies of Treatment Components; Multimodal; Pharmacological (type and dose); Parental Preferences; Protocol Adherence; Beyond Protocol. A curved solid line with an arrow leads down and to the left from the interventions line. The curved line leads to a circle with a solid line border. The adverse events that could result from some of the interventions are listed inside this circle. The adverse events are: physical changes such as stomach aches, tics, weight loss, slowed growth, cardiac events; personality changes; and changes in mental health. Outside the border of the circle and to the upper left, KQ1 and KQ2 are listed to show the association between key questions 1 and 2 and the potential adverse events. Below the adverse events circle is a circle with a dashed line border and a dashed line with an arrow leading from the lower circle to the adverse events circle. The text within the lower circle indicates that adverse events vary by treatment. The thick solid line leading from the population box on the left ends at a large box on the right side of the figure. This box contains a list of the short and long term outcomes of interest. The short term outcomes are: improvement or decline in behavior; improvement or decline in function; diagnosis of Attention Deficit Hyperactivity Disorder; and improvement or decline in quality of life. The long term outcomes are: persistent diagnosis; new onset of psychiatric disorder, initiation of substance use, gambling, driving infractions, teen parenthood, legal charges; and academic attainment, job stability, relationship stability. Located below this box is a circle with a dashed line border. A dashed line with an arrow leads from the circle to the box. The text within the circle describes potential methods for assessing outcomes. These are: Standardized Diagnostic Measures; Data Capture Methods; and Cross-Informant Discrepancies. Above the circle and below the box, KQ1, KQ2, and KQ3 are listed to show the relationship between the key questions, outcomes, and assessment methods.

## Methods

### Identifying Evidence Gaps and Developing PICOTS

We identified the initial evidence gaps from sections throughout the draft review that described limitations preventing the authors from drawing conclusions about a research question. The project team then used information from the draft review regarding eligible populations, interventions, comparators, outcomes, timeframes, and settings (PICOTS) to develop a table showing the relevant PICOTS for each evidence gap.

We identified potential stakeholders representing a broad range of interests and expertise. We scheduled two rounds of conference calls using GoToMeeting® and two rounds of prioritization with the stakeholder group. Prioritization involved using an online prioritization tool we developed that allowed the stakeholders to assign a limited number of “stars” to gaps they considered the highest priority.

A preliminary list of evidence gaps and an analytic framework showing the relationships between the Key Questions, PICOTS elements, and components of the evidence gaps were presented to the stakeholders as part of their orientation materials and discussed at the first stakeholder call. During the first call, we invited stakeholders to comment on and make contributions to the list of evidence gaps. We also reviewed an inventory of ongoing research studies, developed by the project team through searching online research registries, to help identify new data that might be pertinent to evidence gaps. After receiving stakeholder input, project investigators revised the list of evidence gaps and applied the PICOTS elements to the new and revised gaps.

### Criteria for Prioritizing Evidence Gaps

To complement the stakeholders’ own perspectives during the prioritization process, we provided the stakeholders with a modified version of the Effective Health Care Program Selection Criteria.

### Engaging Stakeholders to Prioritize Evidence and Develop Research Needs

After the first call, we asked the stakeholders to assign a limited number of stars to the gaps they viewed as the highest priority. During the second call, we reviewed and discussed the results of the first prioritization exercise, finalized the upper tier of evidence gaps, asked stakeholders for feedback on the PICOTS, and invited thoughts on potential research designs for these upper tier gaps. Following this discussion, we applied the updated PICOTS framework to the upper tier evidence gaps and translated them in to research questions. We then invited the stakeholders to reprioritize only the upper tier of the evidence gaps using the online tool to create a final list of prioritized research needs.

### Developing Research Questions and Determining Potential Research Designs

We applied research design considerations to the top-ranked research needs. We did not ask stakeholders to rank research designs or provide input to the proposed research designs. The final list of prioritized research needs was not shared with the stakeholders until the public comment period of the draft report.

## Results

### Prioritized Future Research Needs and Justification for Urgency

From the 29 original evidence gaps, 8 were deemed by the stakeholders as the highest priority research needs, representing roughly the top quartile of the original list (Table B). In this executive summary, we present the research need, the associated PICOTS, and the research teams initial views of the potential study designs that could be used to address the priority research need. A discussion of the potential study design considerations, including issues of validity, resources required, ability to recruit subjects or obtain data, and potential ethical, legal, or social issues, may be found in the full FRN report.

Table B Eight highest priority research needs

Research Need
For people of all ages diagnosed with ADHD, what are the most accurate, brief standardized tools for diagnosis and outcome measurement that can be administered in generalizable practice settings and used on a repeated basis, integrated into clinical care?
For children less than 6 years old with disruptive behavior disorder or ADHD, what are the comparative efficacy, effectiveness, and harmfulness of the available pharmacological treatments, singularly or in combination with other pharmacologic interventions?
For children less than 6 years old with disruptive behavior disorder or ADHD, what are the comparative efficacy and effectiveness for patient outcomes of differing combinations of psychosocial and pharmacological treatments for those who either are initiating treatment with psychosocial therapies or who have not improved on their current therapy? Are there discrete patient-level predictors that favor a particular treatment strategy?
For people of all ages diagnosed with ADHD (and especially adolescents and adults), what methods provide the most useful data collection, assessment of prevalence, case identification, and outcomes measurements for studies involving epidemiologic surveys and administrative databases?
For children less than 6 years old with disruptive behavior disorder or ADHD, what are the comparative efficacy and effectiveness of specific psychosocial treatments alone compared with pharmacological treatments alone or in combination with psychosocial treatments for patient outcomes?
For people age 6 years or older with ADHD, what are the comparative long-term outcomes for the available psychosocial and pharmacological treatments?
Among children less than 6 years old with disruptive behavior disorder or ADHD, what is the relative/comparative efficacy of key components of psychosocial treatment programs? These might include the relative efficacy of specific parent training compared with treatment components targeting the child, or the efficacy of variants in psychosocial treatment service delivery that allow flexibility for parental preferences compared with those that do not.
For people age 6 years or older with ADHD, which specific sociodemographic, baseline clinical characteristics, and neurobiological features predict a positive treatment response with respect to patient outcomes?

ADHD = attention deficit hyperactivity disorder

### Details of Future Research Needs

#### Research Need

- For people of all ages diagnosed with ADHD, what are the most accurate, brief standardized tools for diagnosis and outcome measurement that can be administered in generalizable practice settings and used on a repeated basis, integrated into clinical care?

P | I | C | O | T | S
All ages Diagnosed with ADHD | N/A | Feasible tools would be compared with reference standards for diagnosis, outcomes | Validation of instrument compared with reference standard | N/A | a. Epidemiological and naturalistic research settings; b. Clinical trials (efficacy); c. Practice-based research settings (effectiveness)

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; N/A = not applicable; O = outcomes; P = populations; S = settings; T = timeframes

##### Considerations for Potential Research Designs

- Psychometric testing

#### Research Need

- For children less than 6 years old with disruptive behavior disorder or ADHD, what are the comparative efficacy, effectiveness, and harmfulness of the available pharmacological treatments, singularly or in combination with other pharmacologic interventions?

P | I | C | O | T | S
Age < 6 years Diagnosed with ADHD or disruptive behavior disorder | Pharmacological treatments, as single agent and/or medication combination | Other single or combined pharmacological treatments (e.g., stimulants vs. nonstimulants) | Outcomes for children and parents^*^ | Months/years | Private clinic, community clinic, school, home

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; O = outcomes; P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence, and harms, such as behavioral side effects, sleep difficulties, appetite/metabolic concerns, and cardiovascular changes.

##### Considerations for Potential Research Designs

- Randomized controlled trials (RCTs)
- Retrospective cohort studies
- Meta-analysis of individual participant data

#### Research Need

- For children less than 6 years old with disruptive behavior disorder or ADHD, what are the comparative efficacy and effectiveness for patient outcomes of differing combinations of psychosocial and pharmacological treatments for those who either [underlined: are initiating treatment] with psychosocial therapies or who [underlined: have not improved on their current therapy]? Are there discrete patient-level predictors that favor a particular treatment strategy?

P | I | C | O | T | S
Age < 6 years Diagnosed with ADHD or at risk for ADHD or diagnosed with disruptive behavior disorder (including oppositional defiant disorder (ODD) and conduct disorder (CD) | Initial treatment with psychosocial and/or pharmacologic treatments or Addition of a psychosocial and/or pharmacological treatment to an existing treatment after treatment failure | Initial treatment with psychosocial and/or pharmacologic treatments or Continuation of existing treatment without addition of psychosocial and/or pharmacologic treatment or switch to different treatment | Outcomes for children and parents^*^ | Months/years | Private clinic, community clinic, school, home

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; O = outcomes; P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence, and harms, such as behavioral side effects, sleep difficulties, appetite/metabolic concerns, and cardiovascular changes.

##### Considerations for Potential Research Designs

- RCTs

#### Research Need

- For people of all ages diagnosed with ADHD (and especially adolescents and adults), what methods provide the most useful data collection, assessment of prevalence, case identification, and outcomes measurements for studies involving epidemiologic surveys and administrative databases?

P | I | C | O | T | S
All ages Diagnosed with ADHD | N/A | a. Education system; b. Health insurance; c. Providers | Evidence-based performance measures (methods) | N/A | Population-based surveys

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; N/A = not applicable; O = outcomes; P = populations; S = settings; T = timeframes

##### Considerations for Potential Research Designs

- Expert panel
- Secondary data analyses of epidemiological and treatment studies

#### Research Need

- For children less than 6 years old with disruptive behavior disorder or ADHD, what are the comparative efficacy and effectiveness of specific psychosocial treatments alone compared with pharmacological treatments alone or in combination with psychosocial treatments for patient outcomes?

P | I | C | O | T | S
Age <6 years Diagnosed with ADHD or at risk for ADHD or diagnosed with disruptive behavior disorder (including ODD and CD by DSM) | Psychosocial interventions alone (including parent training and school-based interventions) | Pharmacological treatments, alone or in combination with psychosocial treatments | Outcomes for children and parents^*^ | 6 months/1 year | Private clinic, community clinic

ADHD = attention deficit hyperactivity disorder; C = comparators; CD = conduct disorder; DSM = Diagnostic and Statistical Manual; I = interventions; O = outcomes; ODD = oppositional defiant disorder P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence.

##### Considerations for Potential Research Designs

- RCTs

#### Research Need

- For people age 6 years or older with ADHD, what are the comparative long-term outcomes for the available psychosocial and pharmacological treatments?

P | I | C | O | T | S
Age≥ 6 years Diagnosed with ADHD | Psychosocial and/or pharmacological treatments | Other psychosocial and/or pharmacological treatments | Outcomes for children and parents^*^ | Months/years | Private clinic, community clinic, school, home

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; O = outcomes; P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence, and adverse events/harms.

##### Considerations for Potential Research Designs

- Extensions of RCTs
- Retrospective cohort study

#### Research Need

- Among children less than 6 years old with disruptive behavior disorder or ADHD, what is the relative/comparative efficacy of key components of psychosocial treatment programs? These might include the relative efficacy of specific parent training compared with treatment components targeting the child, or the efficacy of variants in psychosocial treatment service delivery that allow flexibility for parental preferences compared with those that do not.

P | I | C | O | T | S
Age < 6 years Diagnosed with ADHD or at risk for ADHD or diagnosed with disruptive behavior disorder (including ODD and CD by DSM) | Variety of components as a part of a psychosocial treatment program | A different collection of components of a psychosocial treatment program so as to allow isolation of the effect of specific components | Outcomes for children and parents^*^ | Months/Years | Private clinic, community clinic, school, home

ADHD = attention deficit hyperactivity disorder; C = comparators; CD = conduct disorder; DSM = Diagnostic and Statistical Manual; I = interventions; O = outcomes; ODD = oppositional defiant disorder P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence.

##### Considerations for Potential Research Designs

- RCTs

#### Research Need

- For people age 6 years or older with ADHD, which specific sociodemographic, baseline clinical characteristics, and neurobiological features predict a positive treatment response with respect to patient outcomes?

P | I | C | O | T | S
Age ≥6 years Diagnosed with ADHD | Any treatment for ADHD | a. Inter-subgroup comparisons (e.g., male versus female); b. Subgroup versus all ADHD subjects (e.g., comorbidity vs. no comorbidity, inattentive subtype vs. combined subtype);; c. Correlation with quantitative traits (e.g., neuropsychological dysfunction) | Outcomes for children and parents^*^ | Months/Years | Private clinic, community clinic, school, home

ADHD = attention deficit hyperactivity disorder; C = comparators; I = interventions; O = outcomes; P = populations; S = settings; T = timeframes

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence.

##### Considerations for Potential Research Designs

- Secondary analysis of existing cohort studies and randomized trials
- Consensus conference

## Discussion

The final list of research needs incorporated a broad spectrum of issues. The needs ranged from epidemiological considerations to more clinically or treatment-oriented issues. The final list includes two epidemiological needs involving all ages, four clinically oriented needs for those younger than 6 years old, and two issues for those age 6 years and older. For the younger group, the stakeholders prioritized research needs that would guide the selection of the most efficacious and effective medication and psychosocial interventions. For the older age group, stakeholders prioritized a need for studies to evaluate the relationship between patient-level characteristics and treatment response (similar to a need in the younger group) and one for the comparative evaluation of long-term outcomes.

We proposed RCTs as the optimal study design for many questions. However, trials designed to compare components of different interventions or those designed to evaluate the role of patient-level predictors on treatment response would require very large sample sizes, on the order of 500 to 600 participants. For comparison, the major longitudinal study of ADHD to date, the MTA, had a sample size of 579. It is possible that some of these questions could be evaluated with complex secondary data analysis techniques.

Challenges presented by this process include scheduling conflicts, which led to incomplete participation from some members. Other key challenges involved the need to create a list of clear, concise gaps and the need to remain faithful to the language and intent of the findings of the original ADHD review. Further, identifying appropriate cut points for priority levels is an ongoing challenge. Finally, the stakeholder process is not intended to delineate a numeric rank order of research needs and the final results all should be seen as highest priority needs.

## Conclusions

In this project, we worked with a group of stakeholders to refine 29 identified research gaps and transform them into eight highest priority research needs in the field of ADHD. These highest-level needs included a broad range of issues cutting across age range (above and below 6 years old), key clinical issues, and epidemiological and measurement concerns. Within this group of eight, clear themes emerged: the need for improved measurement tools, more generalizable study populations and settings, longer followup periods, more understanding of patient-level predictors of response, and more comparative evaluation of psychopharmacologic, psychosocial, and combination interventions across age ranges. PICOTS construction aided our consideration of study design issues and our sample power analyses demonstrated the clear pragmatic barriers that many of the potential designs will present. Advanced secondary data-analysis methods may allow some of these complex questions to be addressed in a more cost-effective manner but will not be able to fully replace the need for new large, long-term trials to evaluate these complex research needs in ADHD.