# Discussion

The purpose of this project was to utilize a structured approach to further refine and prioritize specific areas of future research in the area of attention deficit hyperactivity disorder (ADHD) that were necessary to sufficiently address Key Questions in the review, Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-risk Preschoolers; Long-Term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment.1 This project worked to clearly identify evidence gaps described in the report, work with stakeholders to prioritize this list of gaps and transform them into research needs, further prioritize these needs, and consider evidence gaps, populations, interventions, comparators, outcomes, timeframes, and settings (PICOTS) and potential future study designs for the highest prioritized needs.

In regards to our structured stakeholder engagement process, we were grateful to the diverse and enthusiastic team of individuals who provided the needed depth of knowledge in the broad and complex field of ADHD. The stakeholder group included clinicians, advocates, researchers, education specialists, and funders. Our conference calls before and after the first round of prioritization revealed several key themes that helped inform our development of the gap list. These themes included a desire for improved generalizability of study populations and settings, emphasizing comorbidity over diagnostic purity and community-based settings over traditional academic or industry-based research clinics. They emphasized the importance of longer term study periods (years vs. months) and made special note of the desire for epidemiological long-term studies akin to The Framingham Study,24 well known in the field of cardiovascular health. They also highlighted a concern about high dropout rates and indicated an interest in better understanding how adherence to interventions influences outcomes. A final theme that emerged was the desire for a better understanding of how patient-level predictors might influence treatment choice. This process of refinement helped create a list of 29 research gaps that were based on those derived from the initial ADHD evidence review but also reflected the perspectives of the stakeholders. Our initial prioritization exercise revealed 16 higher-priority gaps that were converted into 16 research needs.

The final list of eight highest ranking research needs incorporated a broad spectrum of issues. The needs identified ranged from epidemiological considerations to more clinically or treatment-oriented research needs. Two epidemiological needs were identified. The first involved the need for identification of best methods for data collection, prevalence assessment, case identification, and outcomes measurement for studies involving epidemiologic surveys and administrative databases. The second epidemiological need centered on the desire for accurate and brief standardized case identification and outcome measurement tools designed for use in practice-based research settings and actual clinical practice.

The more clinically oriented needs included four issues from the younger age group (younger than 6 years) and two issues from older age group (6 years and older). For the younger group, the stakeholders prioritized the need for efficacy and effectiveness studies of medication, both alone and in combination. In conference call discussions, stakeholders had indicated concern that combination pharmacotherapy has not been evaluated in the younger age group, yet is known to occur frequently in practice. They also ranked highly the need for efficacy and effectiveness studies of medication and psychosocial interventions alone or in various combinations with one another. Also in conference calls, stakeholders discussed the desire for a large, long-term, multisite trial comparing medication to psychosocial intervention with combination treatment for the younger age group. The stakeholders also prioritized a need to develop studies that would evaluate what types of unidimensional (psychosocial intervention alone) or multidimensional (psychosocial with medication) treatment packages are optimal for certain subgroups of children under the age of 6 years. For example, what types of interventions are best for treatment-naïve individuals and what might be best for treatment nonresponders? And, how do patient-level characteristics such as sex, socioeconomic status, or presence of comorbidities such as learning disorders or anxiety disorders affect the effectiveness and choice of treatment? Finally, for the younger group, the stakeholders emphasized with their ranking the need to disaggregate psychosocial treatment packages into their subparts (e.g., child-focused interventions, school-based behavioral intervention, parent training) and evaluate their relative efficacy.

For the older age group (6 years old and older), one of the more clinically oriented research needs revealed a desire for studies that would evaluate the relationship between patient level characteristics and treatment response. Similar to the research need described above regarding optimal treatments for those less than 6 years old, this need reflects an interest in identifying whether patient-level characteristics can inform selection of specific interventions. This area of needs perhaps points to a recognition that the complexity of the field and heterogeneity of those affected by ADHD may well demand a more personalized approach to intervention choice in the future. Finally, for the older age group, the stakeholders prioritized the need for studies that allow for the comparative evaluation of long-term outcomes such as educational/academic outcomes, social functioning, employment outcomes, and criminality.

In our consideration of potential study designs, we proposed RCTs as the optimal study design for many questions. Our consideration of relevant design characteristics and sample size was informative to illustrate the wide range of complexity and resources that would be required to undertake some of the potential trial designs. For example, single and combination pharmacotherapy efficacy trials for children less than 6 years old are likely challenged by the demands of long-term followup more so than design complexity and sample size demands. However, trials designed to compare types of interventions (for example, comparing subcomponents of psychosocial intervention packages) or those designed to evaluate the role of patient-level predictors on treatment response would require very large sample sizes. This holds true even when considering theoretical high levels of repetition of measures during the study period. Even when the known effect sizes of the compared interventions is large, the sample size requirements may prove prohibitive. In such cases, sample size and cost will need to be weighed carefully against the importance of the research question. Any part of this consideration would also need to address bioethical concerns of trials involving those less than 6 years old.

It is possible that some of these questions could be evaluated with complex secondary data analysis techniques. Meta-analysis is a commonly employed tool in comparative effectiveness research but may not be a feasible tool in all situations because of a lack of studies in an area or because of the heterogeneity of populations and measurement tools across existing studies. However, in some situations where original raw data from previously completed studies could be shared between investigators, advanced techniques of data pooling could potentially be utilized to deal with the heterogeneity problem. This pooling may allow researchers to ask comparative effectiveness questions and perform subgroup analyses without conducting new large trials in some situations. This set of data-pooling techniques when employed in the psychological sciences is sometimes termed integrative data analysis.25

The nature of the stakeholder process is associated with certain limitations. While stakeholder input was valuable, scheduling challenges led to incomplete participation from some members. To accommodate stakeholder schedules, we provided multiple time slots for the calls, meaning that the stakeholder group was not identical on each call. Despite the group’s clear general collegiality, some calls were dominated by stakeholders who were more naturally inclined to present their opinions, which may have led to the crowding out of the opinions of others. Because of this common characteristic of such group processes, we encouraged stakeholders to email thoughts to the study team, and we received multiple communications. Other key challenges related to gap development and presentation. The process created a challenging tension between the need to create a list of clear, concise gaps and the need to remain faithful to the language and intent of the findings of the original ADHD evidence review. Although this balance was difficult to strike, it may represent a strength of the process in that neither the findings of the systematic review nor the views of the stakeholder panel fully dominate the final product. Finally, our report was based on a draft of the final ADHD CER, so specifics of the final report may slightly differ from what we report here.

We organized the gaps by Key Questions from the original ADHD review. Thus, some gaps may have appeared quite similar with differences only in the age range of the target study population, for example. This required that stakeholders take careful note of the subtleties between some gaps and needs when going through the ranking exercises. Some stakeholders may have been more accustomed to considering research gaps and needs from their particular field of work and might have found it difficult to interpret and prioritize research questions developed and organized by other authors. Our research team and the stakeholders raised the question of whether gaps might be made more digestible if organized by theme or domain (for example, one proposed schema broke the gaps into methodologic, treatment intervention oriented, and outcome oriented). How to best organize a list of gaps for presentation to a group of stakeholders for their consideration remained a question for the team at project completion and will be an important ongoing issue for future FRN projects. We chose not to stratify the needs by area, since the stakeholders might view some content areas as more important than others. In relation to prioritization exercises and interpretation of voting results, the dominant challenge was in identifying appropriate cut points for priority levels. We worked to minimize the risk of deprioritizing gaps or needs arbitrarily by erring on the side of inclusion when cut points were not clear. The stakeholder process is not intended to delineate a clear rank order of research needs. However, the structured process used in this project may prove to be a viable way of reaching relative consensus on research priorities in this broad and complex topic area.