# Conclusions

In this project, we worked with a group of stakeholders to refine 29 identified research gaps and transform them into eight highest priority research needs in the field of attention deficit hyperactivity disorder. These highest level needs included a broad range of issues cutting across age range, key clinical issues, and epidemiological concerns. Within this group of eight, clear themes emerged: the need for improved measurement tools, more generalizable study populations and settings, longer followup periods, more understanding of patient-level predictors of response, and more comparative evaluation of psychopharmacologic, psychosocial, and combination interventions across age ranges. Construction of evidence gaps, populations, interventions, comparators, outcomes, timeframes, and settings (PICOTS) aided our consideration of study design issues, and our sample power analyses demonstrated the clear pragmatic barriers that many of the potential designs will present. Advanced secondary data-analysis methods may allow some of these complex questions to be addressed in a more cost-effective manner but will not be able to fully replace the need for new large, long-term trials to evaluate these complex research needs in attention deficit hyperactivity disorder.