# Background

## Context

This Future Research Needs (FRN) report is based on a draft Agency for Healthcare Research and Quality Comparative Effectiveness Review (CER) titled, Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-Risk Preschoolers; Long-Term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment.1 The purpose of the review was to synthesize recent research regarding treatment for preschoolers, long-term effectiveness, and variability in prevalence, diagnosis, and treatment for people of all ages. The aims of the review were to (1) critically examine the comparative long-term effectiveness and adverse events of interventions for attention deficit hyperactivity disorder (ADHD) (pharmacological, psychosocial, or behavioral and the combination of pharmacological and psychosocial or behavioral interventions); (2) critically examine the effectiveness and adverse events of interventions in preschool children with clinically significant disruptive behavior, who are, therefore, at high risk for ADHD; and (3) summarize what is known about patterns of identification and treatment for the condition. The draft review is based on literature searches that were conducted on December 1, 2009. The review was posted for public comment in October 2010. Publication of the final review is in progress, which will include an updated literature search.

The review examined factors such as geography, sociodemographics, temporal aspects, and provider type. The Key Questions (KQs) for the review were as follows:

- KQ 1: Among children less than 6 years of age with Attention Deficit Hyperactivity Disorder or Disruptive Behavior Disorder, what are the effectiveness and adverse event outcomes following treatment?
- KQ 2: Among people 6 years of age or older with Attention Deficit Hyperactivity Disorder, what are the effectiveness and adverse event outcomes following 12 months or more of any combination of follow-up or treatment, including, but not limited to, 12 months or more of continuous treatment?
- KQ 3: How do (a) underlying prevalence of ADHD, and (b) rates of diagnosis (clinical identification) and treatment for ADHD vary by geography, time period, provider type, and sociodemographic characteristics?

## Importance of Disease

As noted by the authors of the original CER1, some evidence suggests that rates of identification and treatment for people with ADHD have increased in recent years;2-4 however, prescription patterns and variations indicate that increases in identification may be linked with changes in practice rather than an increase in the underlying prevalence of the disorder.5,6 In fact, the underlying prevalence of the disorder in children appears to have been relatively stable since the 1980s, to the extent that it has been measured using identical methods.7 Increases in identification and treatment have occurred primarily among girls and older children consistent with changes in clinical guidelines.3,8 Increases in off-label prescription of psychotropic medications for very young children have also been observed, presumably for preschoolers identified with ADHD or disruptive behavior.9

Clinically significant ADHD is often associated with concurrent oppositional and aggressive behaviors, anxiety, low self-esteem, and learning disabilities. Symptoms generally interfere with academic and behavior functioning at school and may also disrupt family and peer relationships. ADHD begins before children enter school, although it is most commonly identified and treated in primary school, ages 7 to 9 years.10 In the preschool age group, ADHD is characterized not only by impairment in attention span, excessive impulsivity, and overactivity, but is also frequently accompanied by additional disruptive behavior symptoms, including severe temper tantrums; demanding, uncooperative behavior; and aggressiveness.11 Although levels of symptoms decrease with age, the majority of children with ADHD continue to show impairment relative to same-age peers throughout adolescence and into adulthood. Estimates of prevalence of ADHD among adults worldwide is 2.5 percent.12

Multiple short-term studies show that psychostimulant medications such as methylphenidate (MPH), dextroamphetamine (DEX), or mixed amphetamine salts (MAS) effectively decrease the core symptoms of ADHD and associated impairment, and that they are generally well tolerated but can be associated with common side effects.13 These studies are generally performed in school-age children, and there is less evidence in preschoolers14 and adults.15,16 Several extended release (XR) preparations of psychostimulants developed in recent years are aimed at improved adherence and symptom control throughout the day as well as decreased abuse potential.17 Nonstimulants (e.g., alpha-adrenergic agents and atomoxetine [ATX]) have also been developed and found to be helpful in controlling symptoms with few adverse events.18 However, in general the benefits of medications wear off when they are discontinued.

Because ADHD is a chronic disorder, many children, teens, and adults may stay on medications for years at a time, but little information is available to patients and physicians regarding long-term effects or the natural history of the disorder as children mature into adulthood. The 2003 United States National Survey of Child Health (NSCH) estimated that 4.4 million children ages 4 to 17 in the United States had a diagnosis of ADD or ADHD, of whom 56 percent were currently taking medication.19 The psychostimulants used to treat older children and adults with ADHD are not approved for use in children less than 6 years old; therefore, treatments for this population emphasize nonpharmaceutical interventions prior to medication. Recent reviews of treatments for preschoolers with ADHD emphasize use of parenting interventions prior to medication based on general clinical consensus. However, little information exists that documents the effectiveness of either medication or nonmedication interventions for ADHD in this age group. Off-label use of medications in the preschool population is, however, common.20

## Findings of the Draft Comparative Effectiveness Review

The authors of the draft ADHD review found that the evidence for KQ 1 supported the use of parent behavior training interventions for preschoolers as an effective intervention both for oppositional behaviors and for ADHD symptoms where measured, with no adverse events reported. The largest barrier to successful completion of the intervention is parent attrition. Preliminary efforts to examine modes of service delivery to accommodate parent preferences suggest that such adjustments do not interfere with effectiveness as long as the program is delivered as designed. For preschoolers, psychostimulant medications are also generally safe and efficacious for improving behavior and can provide benefits in addition to parent training. However, adverse events, especially irritability and moodiness, can lead to discontinuation over extended periods of time, and use for several months to a year affects growth rate to a small degree. The addition of school-based interventions to parent training appears to be more useful for disadvantaged populations, although benefits diminish following discontinuation of the intervention.1

For KQ 2, the authors found that the long-term effectiveness and safety of several psychostimulants, ATX, and guanfacine XR have been examined prospectively in children older than 6 years and adolescents. All of these agents are efficacious for control of inattention and overactivity for extended periods of time, and few serious adverse events are noted. Fewer individuals discontinue psychostimulants and ATX than guanfacine XR due to adverse events. Placebo-controlled discontinuation trials are few, one in children receiving amphetamines, and two others after 1 year and again after 2 years of use in children receiving ATX. These trials suggest that some individuals continue to benefit and others no longer benefit, following 12, 15, or 24 months of continuous treatment with medication.1

Evaluation of long-term outcomes following interventions for ADHD is complex due to multiple patterns of services used. The best data are available through multiple publications produced by the 8-year followup of the Multimodal Treatment Study of Children with Attention Deficit Hyperactivity Disorder (MTA) study.21 By 3 years after initiation, no single intervention group showed superior benefit, which is likely due to individuals obtaining a complex range of interventions in the community. The majority of children who received an intervention maintained improvements in functioning, although they were not improved enough to match nonclinical comparison groups. A small proportion returned to previous levels of poor functioning over time. No clear relationship was identified between duration of medication use and outcomes. Other cohort studies suggest that long-term use of medication improves grade retention and academic achievement, and may lessen onset of substance use disorders as well as oppositional defiant, conduct, anxiety, and depressive disorders.1

The findings for KQ 3 included results from a systematic review and meta-regression that placed the worldwide pooled prevalence estimate of ADHD among those 18 years old or younger at 5.29 percent (95% confidence interval [CI]: 5.01 to 5.56), with more boys than girls identified and the highest rates of disorder occurring in the 5- to 10-year-old age group. Primary sources of variability were identified as methodological rather than geographic, and included differences in requirements for impairment, diagnostic criteria, and source of information. Fewer studies are available that document prevalence in adult, adolescent, or preschool age groups, which likely reflects a lack of clarity regarding current diagnostic criteria in these groups. Information about clinical identification and treatment (available through administrative and prescription data and health surveys) documents that psychostimulant use for ADHD increased throughout the early to mid-1990s and slowed in the late 1990s and early 2000s in the United States. Disparities are noted, with more boys than girls treated and more Caucasians than Hispanics or African-Americans receiving medication treatment once diagnosed in the United States. Rates of identification and treatment also vary from state to state. Nonpharmacologic interventions are not documented.1

## Objective

The purpose of this FRN project is to work with a diverse group of stakeholders to: (1) identify the persisting evidence gaps that impede decisionmaking for clinicians, researchers, policymakers, and consumers, and (2) prioritize the stakeholders’ research needs related to the prevalence, diagnosis, and treatment of ADHD in children and adults.

## Evidence Gaps

The draft review identified several topics for which authors found little or no evidence to draw conclusions. We developed the list of evidence gaps in Table 1 based on information gleaned from the draft review. We then applied the PICOTS from the CER inclusion/exclusion criteria and developed an analytic framework to show the relationships between the evidence gaps, PICOTS, and Key Questions (Figure 1). We modified the list of evidence gaps after stakeholder engagement. The specific gaps changed or added by the stakeholders during and after the first conference call are indicated with an asterisk. The original list of evidence gaps gleaned from the review and presented to the stakeholders during the first conference call is in Appendix A.

Table 1 Preliminary evidence gaps by Key Question

Evidence Gap | Relevant Key Question
For children less than 6 years old with disruptive behavior disorder or ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs (e.g., parent training and summer behavior treatment programs), alone or in combination with pharmacological interventions, compared with other psychosocial treatment programs, alone or in combination with pharmacological interventions. | KQ 1
For children less than 6 years old with disruptive behavior disorder or ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs alone compared with pharmacological treatments, alone or in combination with psychosocial treatments. | KQ 1
Among children less than 6 years old with disruptive behavior disorder or ADHD, there is a paucity of research examining positive child treatment results for variants on multimodal interventions (e.g., combinations of parent behavior training, summer behavior treatment programs, school-based interventions, or other cross-sector evaluations), alone or in combination with pharmacological interventions, and effects on specific subgroups. | KQ 1
For preschoolers with disruptive behavior disorder or ADHD, there are few efficacy and effectiveness studies on prescriptive treatments or optimal circumstances for adding specific psychosocial and/or pharmacological treatment components based on the child’s needs. | KQ 1
Among people less than 6 years old with disruptive behavior disorder or ADHD, there is a lack of high-quality studies on efficacy and effectiveness of biofeedback and working memory training. | KQ 1
Among children ageless than 6 years with disruptive behavior disorder or ADHD, there is a paucity of studies documenting adverse events or noncompliance rates for psychosocial interventions including parent training and school-based interventions. | KQ 1
For children less than 6 years of age with ADHD, limited data are available on the influence of parental preferences regarding treatment approaches or modes of service delivery on short- and long-term outcomes. | KQ 1
Among children less than 6 years old with disruptive behavior disorder or ADHD, there is a paucity of studies that disassemble the key components of available psychosocial treatment programs (e.g., specific parent training techniques compared to treatment components targeting the child and variants in service delivery to accommodate parental preferences). | KQ 1
Conflicting results from treatment studies of children less than 6 years old with disruptive behavior disorder or ADHD show improvements in ADHD symptoms when the parent behavior training protocol is flexible and when the protocol is not flexible. Among children less than 6 years old with disruptive behavior disorder or ADHD, studies comparing the relative efficacy of flexible versus nonflexible parent behavior training protocols are not available. | KQ 1
Limited data are available from studies with appropriate comparison groups about long-term outcomes for preschool interventions. | KQ 1
Among children less than 6 years old with ADHD, there is a paucity of prospective studies that compare the efficacy, effectiveness, and harms of single and/or combination pharmacotherapies with other single or combined pharmacotherapies (e.g., stimulants vs. nonstimulants).^*^ | KQ 1
For children age 6 years or older with ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs (e.g., parent training and summer behavior treatment programs), alone or in combination with pharmacological interventions, compared with other psychosocial treatment programs, alone or in combination with pharmacological interventions. | KQ 2
For children age 6 years or older with ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs alone compared with pharmacological treatments, alone or in combination with psychosocial treatments. | KQ 2
Among children age 6 years or older with ADHD, there is a paucity of research examining positive treatment results for variants on multimodal interventions (e.g., combinations of parent behavior training, summer behavior treatment programs, school-based intervention) alone or in combination with pharmacological interventions, and effects on specific subgroups. | KQ 2
For people age 6 years or older with ADHD, few efficacy and effectiveness studies are available on prescriptive treatments or optimal circumstances for adding specific psychosocial and/or pharmacological treatment components based on the person’s needs. | KQ 2
Among people age 6 years or older with ADHD, there is a lack of high-quality studies on efficacy and effectiveness of biofeedback and working memory training. | KQ 2
Among individuals age 6 years or older with ADHD, there is a paucity of studies documenting adverse events or noncompliance rates for psychosocial interventions including parent training and school-based interventions. | KQ 2
For people age 6 years or older with ADHD, limited data are available examining longer term follow-up of psychosocial and pharmacological ADHD treatments with appropriate comparison groups for long-term outcomes including academic and educational outcomes. | KQ 2
Among people age 6 years or older with ADHD, there is a paucity of prospective combination pharmacological studies (e.g., combination pharmacotherapy treatment) as well as studies that follow individuals no longer requiring medication. | KQ 2
For people age 6 years or older, there is a lack of evidence to support standardized methods for improving adherence to ADHD medications.^*^ | KQ 2
Among people age 6 years or older with ADHD, there is a paucity of studies that examine mediators and moderators of positive treatment response. The extant literature provides limited information about variations in treatment response by specific sociodemographic characteristics (e.g., low socioeconomic status, gender, different racial or ethnic groups) and baseline clinical indices (e.g., comorbidity with other psychiatric disorders, ADHD subtypes, comorbid developmental disorders, comorbid learning disabilities, language impairments, reading or mathematics disorders). | KQ 2
For people age 6 years and older with ADHD, standardized outcome measures such as global impairment scales, quality of life scales, and measures that capture school performance learning capacity, social and emotional functioning, social competence, and functional capacity are needed to compare study outcomes from different cohorts. | KQ 2
Research among people with ADHD age 6 years and older that compares efficacy as measured by different data-capturing methods such as child self-rating scales, parent rating scales, and semistructured interviews is limited. | KQ 2
Research is limited on the direct and relative effects of discrepancies among multiple informants (e.g., parents, children, teachers, clinicians) on the diagnosis of ADHD and the effectiveness of treatments for people of all ages with ADHD. | KQ 2, 3
The extant literature lacks evidence-based measures for assessing prevalence and treatment outcomes for people of all ages with ADHD on a comparable metric. Standardized methods of data collection, case identification, and outcomes measurement in epidemiologic surveys and administrative databases are lacking, particularly for adolescents and adults. | KQ 3
There is a paucity of evidence examining the amount of variation in case identification and prevalence across geographic areas, age groups, settings, and cultures, as well as a lack of research examining the causes and consequences of such variation in children’s access to treatment and outcomes. | KQ 3
Diagnostic tools and measurements for outcomes beyond behaviors associated with ADHD (such as social functioning/interaction with peers) are not standardized. This gap includes a need for brief instruments that can be used in generalizable practice settings including epidemiologically valid long-term cohort studies and practice-based research networks.^*^ | KQ 3
Little research is available that addresses the etiology and consequences of geographic variation in treatment patterns of ADHD in all age groups in terms of effect on outcomes. These factors might include cross-sector coordination of health services, family and child factors, provider factors, and availability and type of insurance. | KQ 3
For people of all ages with ADHD, there is a paucity of comparative evidence from practice-based research regarding access to and the use of generalists in combination with specialists compared with referral to specialists in generalizable practice.^*^ | KQ 3

ADHD = attention deficit hyperactivity disorder; KQ = Key Question

* Evidence gaps added by the stakeholders during and shortly after the first conference call.

Figure 1 Analytic framework depicting relationships between Key Questions, populations, interventions, outcomes, and components of evidence gaps

ADHD = attention deficit hyperactivity disorder; KQ = Key Question; SES = socioeconomic status

To the left of center in the figure, a box represents the populations addressed by key questions 1, 2, and 3. These are children less than 6 years of age with disruptive behavior disorder (including Attention Deficit Hyperactivity Disorder (ADHD)) and children 6 years or older, adolescents, and adults with ADHD. Above this box, KQ1, KQ2, and KQ3 are listed to show the relationships between the populations and key questions. Dashed lines with arrows pointing toward the box connect this box to four circles located to the left and above the box. The borders of the circles are dashed lines. The text within the circles describes population characteristics that might influence responses to treatment and methods needed to assess prevalence and treatment outcomes. In the first circle, the text reads, “Sociodemographic Characteristics: Sex, Race/Ethnicity, SES.” In the second circle, the text is, “Psychiatric comorbidity.” In the third circle, the text is. “Comorbid developmental, learning disorders or other disabilities.” And, in the fourth circle the text reads, “Evidence-based performance measures; standardized methods of data collection, case identification, and outcomes measurement.” A thick solid line with an arrow leads to the right from the box representing the populations. This line represents the interventions of interest in the comparative effectiveness review. The interventions are listed as bullet points under the line. These are: pharmacologic, behavioral, and combination pharmacologic and behavioral interventions. Above the line, KQ1, KQ2, and KQ3 are listed to indicate the association between the key questions, interventions, and outcomes of interest. Below the bulleted list of interventions is a circle with a dashed line border. A dashed line with an arrow leads from the circle to the list of interventions. Within the circle is a list of intervention variations. This list is: Prescriptive Treatments; Dismantling Studies of Treatment Components; Multimodal; Pharmacological (type and dose); Parental Preferences; Protocol Adherence; Beyond Protocol. A curved solid line with an arrow leads down and to the left from the interventions line. The curved line leads to a circle with a solid line border. The adverse events that could result from some of the interventions are listed inside this circle. The adverse events are: physical changes such as stomach aches, tics, weight loss, slowed growth, cardiac events; personality changes; and changes in mental health. Outside the border of the circle and to the upper left, KQ1 and KQ2 are listed to show the association between key questions 1 and 2 and the potential adverse events. Below the adverse events circle is a circle with a dashed line border and a dashed line with an arrow leading from the lower circle to the adverse events circle. The text within the lower circle indicates that adverse events vary by treatment. The thick solid line leading from the population box on the left ends at a large box on the right side of the figure. This box contains a list of the short and long term outcomes of interest. The short term outcomes are: improvement or decline in behavior; improvement or decline in function; diagnosis of Attention Deficit Hyperactivity Disorder; and improvement or decline in quality of life. The long term outcomes are: persistent diagnosis; new onset of psychiatric disorder, initiation of substance use, gambling, driving infractions, teen parenthood, legal charges; and academic attainment, job stability, relationship stability. Located below this box is a circle with a dashed line border. A dashed line with an arrow leads from the circle to the box. The text within the circle describes potential methods for assessing outcomes. These are: Standardized Diagnostic Measures; Data Capture Methods; and Cross-Informant Discrepancies. Above the circle and below the box, KQ1, KQ2, and KQ3 are listed to show the relationship between the key questions, outcomes, and assessment methods.