# Appendixes

Appendix A Research Gaps Identified From the Draft Comparative Effectiveness Review

Appendix B Web-Based Prioritization Exercises

Appendix C Effective Health Care (EHC) Program Modified Selection Criteria

Appendix D ADHD (Future Research Needs) Searches for Ongoing Research

Appendix E Future Research Needs—ADHD Evidence Gaps Prioritization Exercise

Appendix F Future Research Needs—ADHD Research Needs