# Future Research Needs—ADHD Research Needs

## Developed From the Upper Tier Evidence Gaps (N = 16)

Numbers are for reference only and do not represent any particular order.

### Research Needs for Those Less Than 6 Years old

1 For children less than 6 years old with disruptive behavior disorder or ADHD, what is the comparative efficacy and effectiveness of specific psychosocial treatments alone compared with pharmacological treatments alone or in combination with psychosocial treatments for patient outcomes^*^?
  * Patient outcomes include: change in ADHD symptoms, behavior problems, social functioning, emotional regulation, executive functioning, treatment adherence, global functioning, academics, and parent competence.
2 For children less than 6 years old with disruptive behavior disorder or ADHD, which research methods will best allow meaningful assessments of long-term outcomes (e.g., identify causal inferences between specific preschool interventions and long-term patient outcomes^*^)? Specifically, what types of comparison groups are appropriate?
3 For children less than 6 years old with disruptive behavior disorder or ADHD, how does parental preference affect the choice of treatment? How do these preferences affect short and long-term patient outcomes^*^?
4 Among children less than 6 years old with disruptive behavior disorder or ADHD, what is the relative/comparative efficacy of key components of psychosocial treatment programs? These might include the relative efficacy of specific parent training compared with treatment components targeting the child, or the efficacy of variants in psychosocial treatment service delivery that allow flexibility for parental preferences compared with those that do not.
5 For children less than 6 years old with disruptive behavior disorder or ADHD, what is the efficacy and effectiveness of psychosocial treatment programs, alone or in combination with pharmacological interventions, compared with other psychosocial treatment programs or to usual care for patient outcomes^*^?
6 For children less than 6 years old with disruptive behavior disorder or ADHD, what is the comparative efficacy and effectiveness for patient outcomes^*^ of differing combinations of psychosocial and pharmacological treatments for those who either are initiating treatment with psychosocial or behavioral therapies or who have not improved on their current therapy? Are there discrete patient-level predictors that favor a particular treatment strategy?
7 For children less than 6 years old with disruptive behavior disorder or ADHD, what is the comparative efficacy, effectiveness, and harmfulness of the available pharmacological treatments, singularly or in combination with other pharmacologic interventions?

### Research Needs for Those 6 Years old or Older

8 For people age 6 years or older with ADHD, what are the most accurate outcome measures available to assess global impairment, quality of life, school performance, learning capacity, social and emotional functioning, social competence, and functional capacity?
9 Among individuals age 6 years or older with ADHD, what are the adverse events and noncompliance rates for psychosocial interventions, including parent training and school-based interventions?
10 For people age 6 years or older with ADHD, what is the comparative efficacy and effectiveness for patient outcomes^*^ of differing combinations of psychosocial and pharmacological treatments for those who either are initiating treatment with psychosocial or behavioral therapies or who have not improved on their current therapy? Are there discrete patient-level predictors that favor a particular treatment strategy?
11 For people age 6 years or older with ADHD, what is the comparative effectiveness of existing methods for improving adherence to ADHD medications?
12 For people age 6 years or older with ADHD, which specific sociodemographic, baseline clinical characteristics,^ and neurobiological features^‡^ predict a positive treatment response with respect to patient outcomes^*^?
  ^ Sociodemographic and baseline clinical characteristics include: sex, socioeconomic status, race, comorbidity with other psychiatric disorders, ADHD subtypes, comorbid developmental disorders, comorbid learning disabilities, language impairments, reading or mathematics disorders.
  ‡ Neurobiological features include: genetic variants and neuroimaging abnormalities.
13 For people age 6 years or older with ADHD, what are the comparative long-term outcomes+ for the available psychosocial and pharmacological treatments?
  + Long-term outcomes include educational measures, which encompass academic outcomes.

### Research Needs for People of all Ages

14 For people of all ages with ADHD, how do access to and use of coordinated care between general practitioners and specialists compare with care from specialists alone with respect to patient outcomes^*^?
15 For people of all ages diagnosed with ADHD, what are the most accurate, brief standardized tools for diagnosis and outcome measurement that can be administered in generalizable practice settings and used on a repeated basis, integrated into clinical care?
16 For people of all ages diagnosed with ADHD (and especially adolescents and adults), what methods provide the most useful data collection, assessment of prevalence, case identification, and outcomes measurements for studies involving epidemiologic surveys and administrative databases?

ADHD = attention deficit hyperactivity disorder