# Future Research Needs—ADHD Evidence Gaps Prioritization Exercise

## Results

Total stars allotted to each gap (N = 10 responders)

Orange line shows cut off between Upper Tier and Lower Tier.

### Ranked List of Evidence Gaps after 1^st^ Round of Prioritization

Upper Tier Evidence Gaps (those receiving 5 or more stars)

Variable Code | Evidence Gap Text | # Stars | # People
EG8 | For people age 6 years or older with ADHD, there are few efficacy and effectiveness studies on prescriptive treatments or optimal circumstances for adding specific psychosocial and/or pharmacological treatment components based on the person’s needs. | 10 | 6
EG21 | Among people age 6 years or older with ADHD, there is a paucity of studies that examine mediators and moderators of positive treatment response. The extant literature provides limited information about variations in treatment response by specific sociodemographic characteristics (e.g., low socioeconomic status, gender, different racial or ethnic groups) and baseline clinical indices (e.g., comorbidity with other psychiatric disorders, ADHD subtypes, comorbid developmental disorders, comorbid learning disabilities, language impairments, reading or mathematics disorders). | 10 | 7
EG22 | For people age 6 years and older with ADHD, standardized outcome measures such as global impairment scales, quality of life scales, and measures that capture school performance learning capacity, social and emotional functioning, social competence, and functional capacity are needed to compare study outcomes from different cohorts. | 10 | 6
EG7 | For preschoolers with disruptive behavior disorder or ADHD, there are few efficacy and effectiveness studies on prescriptive treatments or optimal circumstances for adding specific psychosocial and/or pharmacological treatment components based on the child’s needs. | 9 | 6
EG16 | There are limited data available from studies with appropriate comparison groups about long-term outcomes for preschool interventions. | 8 | 6
EG13 | For children less than 6 years old with ADHD, there are limited data on the influence of parental preferences regarding treatment approaches or modes of service delivery on short- and long-term outcomes. | 7 | 4
EG17 | For people age 6 years or older with ADHD, there are limited data available examining longer term followup of psychosocial and pharmacological ADHD treatments with appropriate comparison groups for long-term outcomes including academic and educational outcomes. | 7 | 5
EG25 | The extant literature lacks evidence-based measures for assessing prevalence and treatment outcomes for people of all ages with ADHD on a comparable metric. Standardized methods of data collection, case identification, and outcomes measurement in epidemiologic surveys and administrative databases are lacking, particularly for adolescents and adults. | 7 | 5
EG27 | There is no standardization of diagnostic tools and measurements for outcomes beyond behaviors associated with ADHD (such as social functioning/interaction with peers). This includes a need for brief instruments that can be used in generalizable practice settings including epidemiologically valid long-term cohort studies and practice-based research networks. | 7 | 5
EG19 | Among children less than 6 years old with ADHD, there is a paucity of prospective studies that compare the efficacy, effectiveness, and harms of single and/or combination pharmacotherapies with other single or combined pharmacotherapies (e.g., stimulants vs. nonstimulants). | 6 | 3
EG1 | For children less than 6 years old with disruptive behavior disorder or ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs (e.g., parent training and summer behavior treatment programs), alone or in combination with pharmacological interventions, compared with other psychosocial treatment programs, alone or in combination with pharmacological interventions. | 5 | 4
EG12 | Among individuals ages 6 years or older with ADHD, there is a paucity of studies documenting adverse events or noncompliance rates for psychosocial interventions including parent training and school-based interventions. | 5 | 4
EG14 | Among children less than 6 years old with disruptive behavior disorder or ADHD, there is a paucity of studies that disassemble the key components of available psychosocial treatment programs (e.g., specific parent training techniques compared to treatment components targeting the child and variants in service delivery to accommodate parental preferences). | 5 | 4
EG20 | For people age 6 years or older, there is a lack of evidence to support standardized methods for improving adherence to ADHD medications. | 5 | 3
EG29 | For people of all ages with ADHD, there is a paucity of comparative evidence from practice-based research regarding access to and the use of generalists in combination with specialists compared with referral to specialists in generalizable practice. | 5 | 4

Lower Tier Evidence Gaps (those receiving 4 or fewer stars)

Variable Code | Evidence Gap Text | # Stars | # People
EG3^*^ | For children less than 6 years old with disruptive behavior disorder or ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs alone compared with pharmacological treatments, alone or in combination with psychosocial treatments. | 4 | 3
EG24 | There is limited research on the direct and relative effects of discrepancies among multiple informants (e.g., parents, children, teachers, clinicians) on the diagnosis of ADHD and the effectiveness of treatments for people of all ages with ADHD. | 4 | 2
EG2 | For children age 6 years or older with ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs (e.g., parent training and summer behavior treatment programs), alone or in combination with pharmacological interventions, compared with other psychosocial treatment programs, alone or in combination with pharmacological interventions. | 3 | 2
EG6 | Among children age 6 years or older with ADHD, there is a paucity of research examining positive treatment results for variants on multimodal interventions (e.g., combinations of parent behavior training, summer behavior treatment programs, school-based intervention) alone or in combination with pharmacological interventions, and effects on specific subgroups. | 3 | 2
EG9 | Among people age 6 years or older with ADHD, there is a lack of high-quality studies on the efficacy and effectiveness of biofeedback and working memory training. | 3 | 2
EG10 | Among people less than 6 years old with disruptive behavior disorder or ADHD, there is a lack of high-quality studies on the efficacy and effectiveness of biofeedback and working memory training. | 3 | 2
EG15 | Conflicting results from treatment studies of children less than 6 years old with disruptive behavior disorder or ADHD show improvements in ADHD symptoms when the parent behavior training protocol is flexible and when the protocol is not flexible. Among children less than 6 years of age with disruptive behavior disorder or ADHD, studies comparing the relative efficacy of flexible versus nonflexible parent behavior training protocols are currently not available. | 3 | 2
EG4 | For children age 6 years or older with ADHD, limited data are available about the efficacy and effectiveness of psychosocial treatment programs alone compared with pharmacological treatments, alone or in combination with psychosocial treatments. | 2 | 1
EG5 | Among children less than 6 years old with disruptive behavior disorder or ADHD, there is a paucity of research examining positive child treatment results for variants on multimodal interventions (e.g., combinations of parent behavior training, summer behavior treatment programs, school-based interventions, or other cross-sector evaluations), alone or in combination with pharmacological interventions, and effects on specific subgroups. | 2 | 1
EG11 | Among children age less than 6 years with disruptive behavior disorder or ADHD, there is a paucity of studies documenting adverse events or noncompliance rates for psychosocial interventions including parent training and school-based interventions. | 2 | 2
EG26 | There is a paucity of evidence examining the amount of variation in case identification and prevalence across geographic areas, age groups, settings, and cultures, as well as a lack of research examining the causes and consequences of such variation in children’s access to treatment and outcomes. | 2 | 2
EG18 | Among people age 6 years or older with ADHD, there is a paucity of prospective combination pharmacological studies (e.g., combination pharmacotherapy treatment) as well as studies that follow individuals no longer requiring medication. | 1 | 1
EG23 | Research among people with ADHD age 6 years and older that compares efficacy as measured by different data-capturing methods such as child self-rating scales, parent rating scales, semistructured interviews is limited. | 1 | 1
EG28 | There is little research addressing the etiology and consequences of geographic variation in treatment patterns of ADHD in all age groups in terms of effect on outcomes. These factors might include cross-sector coordination of health services, family and child factors, provider factors, and availability and type of insurance. | 1 | 1

ADHD = attention deficit hyperactivity disorder

* EG3 was moved to the upper tier at the request of the stakeholders.