# ADHD (Future Research Needs) Searches for Ongoing Research

## VERSION 3—more focused searches, January 18, 2011, limiting to March 2008 (or 2008 where month limit not possible); and a smaller number of terms

### I RePORTER—limited to Active Projects and Award Notice Date greater than February 28, 2008

“attention deficit,adhd”

= 347 results (saved as .csv/Excel files)

### II HSRProj—using the same search as before, and limiting Initial Year range 2008-2011

aggression OR “aggressive behavior” OR aggressiveness OR “agonistic behavior” OR anger OR “attention deficit” OR “attention span” OR addh OR adhd OR “attention deficit and disruptive behavior disorders” OR “attention deficit disorder with hyperactivity” OR “behavior disorder” OR “behavior problems” OR bullying OR “Child Behavior Disorders” OR “conduct disorder” OR “disruptive behavior” OR “disruptive disorder” OR distractability OR hostility OR hyperactive OR hyperactivity OR hyperkinesia OR Hyperkinesis OR hyperkinetic OR “Impulse Control Disorders” OR “Impulsive Behavior” OR impulsiveness OR inattention OR inattentive OR “minimal brain dysfunction” OR “oppositional defiant disorder” OR “self control”

= 57 results. Imported to EndNote, file name = ADHD-HSRProj_v.3(57).enl

### III ClinicalTrials.gov—same strategy as with RePORTER. In advanced search screen, limited to First Received: From 03/01/2008 To 01/18/2011

“attention deficit” OR adhd

= 260 studies. saved as a zip (text) file, filename = CT.govADHDv.3(260).zip

### IV ICTRP (International Clinical Trials Registry Platform) test search strategy and URL sent to Candi Wines and Dan Jonas on 1/18 for them to evaluate the usefulness of the results. Same search strategy as with RePORTER and CT.gov

Advanced Search screen:

http://apps.who.int/trialsearch/AdvSearch.aspx

Search in Condition box:

“attention deficit” OR adhd

Fill in Date of registration between: 03/01/2008 and 01/18/2011

= 124 records for 122 trials found (copied and pasted the text from each record into a Word document)

If the same search is repeated, only moving the search terms to the Title search box, 97 records for 97 trials are found.

Of those, 13 were not in the original search (determined by whether or not the link was blue [unviewed] or purple [viewed])), and all look possibly relevant, so these were appended to the first search.

There was a problem with the results: there were actually between 300-400 results returned, more than the database reported at the conclusion of the query. The librarian copied and saved 155 records in full format. She also created a list of all results in case reviewers would like to see more; the librarian noticed that many of the results were not on topic and also did not contain either of the search terms. Once she noticed that she had saved some irrelevant records, of those remaining on pages 3-4 (records were displayed 100 per page) she only saved records that referred to ADHD or “attention deficit” in the title, but did not notice this database error in time to avoid copying some that were not relevant. Specifically:

#1-#100 look relevant

- #101 is Early Diagnosis and Stem Cell Transplantation for Severe Immunodeficiency Diseases SIDS
- #102 is Effect of Vitamin D Treatment in Primary Hyperparathyroidism
- #103 is Evaluation of the Effect of Bezafibrate on Muscle Metabolism During Exercise in Patients With CPTII and VLCAD Deficiency
- #104 is Effect of Diet-induced Weight Loss on HIV-associated Metabolic Syndrome
- #105 is Effect of vitamin D on the systolic blood pressure in hypertensive patients with low vitamin D levels.
- #106 is Effect of Vitamin D Replacement During Winter Months in Patients With Hypertension
- #107 is Effect of Vitamin D3 on Vascular Function
- #108 is Acute effects of growth hormone on cognitive functioning and related brain physiology in healthy subjects.
- #109 is relevant
- #110 is Effectiveness of generic split adult tablets and paediatric fixed dose combination (FDC) of d4T/3TC/NVP in the treatment of HIV infected Malawian children TrioPed
- #111 is relevant
- #112 is Effects of a supervised exercise program on the physical fitness, immunological function and quality of life of Human immunodeficiency virus (HIV)-Infected Patients.
- #113 is relevant
- #114 is Effects of Dietary Heme/Non-heme Iron and Helicobacter Pylori (Hp) Infection on Maternal Iron-deficiency Anemia and Fetal Growth Outcomes
- #115 is Effects of Vitamin D Supplement Before and During Pregnancy on Birth Weight Gravita
- #116 is Effects of Vitamin D Supplementation in Coronary Artery Disease-patients With Postchallenge Hyperglycemia and Vitamin D Deficiency
- #117 is Effects of Vitamin D Supplementation in Obesity
- #118 is Efficacy and Safety of GSK Biologicals HIV Vaccine in Antiretroviral Therapy (ART)-naïve HIV-1 Infected Persons
- #119 is Efficacy and Safety of Intravenous Ferric Carboxymaltose (FCM) in Patients With Iron Deficiency Anemia (IDA)
- #120 is Efficacy and Safety of Prothromplex Total (Prothrombin Complex Concentrate) in Oral Anticoagulant Reversal
- #121 is Efficacy and safety of strontium ranelate/vitamin D3 combination on vitamin D deficiency in the treatment of osteoporotic patient N/A
- #122 is Efficacy of Cultivated Corneal Epithelial Stem Cell for Ocular Surface Reconstruction
- #123 is Efficacy of Daily Vitamin D3 Supplementation in Normal Weight Adolescents
- #124 is Efficacy of Double Fortified Salt (DFS) to Improve Work Productivity in Women in India DFS #125 is Efficacy of Thrice Weekly Intermittent Short Course Antituberculosis Chemotherapy in Tuberculosis Patients With and Without HIV Infection
- #126 is Epidemiological studies for clinical manifestations and case numbers of inborn errors of ketone body metabolism
- #127 is Epigenetic Markers of B-Cell Function in Low Birth Weight Infants
- #128 is Establishing Fibroblast-derived Cell Lines From Skin Biopsies of Patients With Immunodeficiency or Immunodysregulation Disorders
- #129 is about HIV Tx
- #130 is about CVD/HIV
- #131 is about COPD
- #132-133 are about treating iron deficiency
- #134 is about muscular dystrophy

#135-155 look relevant.

UNDUPLICATED TOTAL WITHOUT ICTRP RESULTS: 664

UNDUPLICATED TOTAL INCLUDING ICTRP RESULTS: 819

## VERSION 2—December 22, 2010 revision (limiting to award or start date from the last 5 years, Humans and English when possible)

### I RePORTER (limited to Active Projects and Award Notice Date greater than January 1, 2006; no limits available for Humans and English)

“LARGE” search, inclusive of all ADHD and related terms used by McMaster

“aggression,aggressive behavior,aggressiveness,agonistic behavior,anger,attention deficit,attention span,addh,adhd,attention deficit and disruptive behavior disorders,attention deficit disorder with hyperactivity,behavior disorder,behavior problems,bullying,Child Behavior Disorders,conduct disorder,disruptive behavior,disruptive disorder,distractability,hostility,hyperactive,hyperactivity,hyperkinesia,Hyperkinesis,hyperkinetic,Impulse Control Disorders,Impulsive Behavior,impulsiveness,inattention,inattentive,minimal brain dysfunction,oppositional defiant disorder,self control”

Still too large at 1864. Not saved.

“MEDIUM” Selected more specific ADHD and related terms

“attention deficit,attention span,addh,adhd,attention deficit and disruptive behavior disorders,attention deficit disorder with hyperactivity,behavior disorder,behavior problems,Child Behavior Disorders,disruptive behavior,disruptive disorder,distractability,hyperactive,hyperactivity,hyperkinesia,Hyperkinesis,hyperkinetic,Impulse Control Disorders,Impulsive Behavior,impulsiveness,inattention,inattentive,minimal brain dysfunction,oppositional defiant disorder”

=1142 results, not saved

“FOCUSED” Results only about AHDH:

“attention deficit,attention span,addh,adhd,attention deficit and disruptive behavior disorders,attention deficit disorder with hyperactivity,child behavior disorders”

=590 results—downloaded 100 or fewer per file, so that abstracts are included when present. For download files larger than 100 records, abstracts are not included. There will also be some duplicates in the files, because RePORTER creates on-the-fly search results from a relational database. If a project has more than one funding agency contributing, the project is listed for each funder. This is the least user-friendly of the three databases searched.

### II HSRProj focused search

This search was left broad because the focus of the database is Health Services Research and Public health, and the size of the database is small, so we want to search it more thoroughly using all terms employed by the McMaster team. So the original search from Dec. 20 was kept:

aggression OR “aggressive behavior” OR aggressiveness OR “agonistic behavior” OR anger OR “attention deficit” OR “attention span” OR addh OR adhd OR “attention deficit and disruptive behavior disorders” OR “attention deficit disorder with hyperactivity” OR “behavior disorder” OR “behavior problems” OR bullying OR “Child Behavior Disorders” OR “conduct disorder” OR “disruptive behavior” OR “disruptive disorder” OR distractability OR hostility OR hyperactive OR hyperactivity OR hyperkinesia OR Hyperkinesis OR hyperkinetic OR “Impulse Control Disorders” OR “Impulsive Behavior” OR impulsiveness OR inattention OR inattentive OR “minimal brain dysfunction” OR “oppositional defiant disorder” OR “self control”

=199 projects saved in an EndNote library 12/20/2010

### III ClinicalTrials.gov

Expert Search of all fields:

Full “LARGE” search was completed and limited to studies First Received between 01/01/2006-12/22/2010:

( aggression OR “aggressive behavior” OR aggressiveness OR “agonistic behavior” OR anger OR “attention deficit” OR “attention span” OR addh OR adhd OR “attention deficit and disruptive behavior disorders” OR “attention deficit disorder with hyperactivity” OR “behavior disorder” OR “behavior problems” OR bullying OR “Child Behavior Disorders” OR “conduct disorder” OR “disruptive behavior” OR “disruptive disorder” OR distractability OR hostility OR hyperactive OR hyperactivity OR hyperkinesia OR Hyperkinesis OR hyperkinetic OR “Impulse Control Disorders” OR “Impulsive Behavior” OR impulsiveness OR inattention OR inattentive OR “minimal brain dysfunction” OR “oppositional defiant disorder” OR “self control” ) [DISEASE] AND ( “01/01/2006” : “12/22/2010” ) [FIRST-RECEIVED-DATE]

=786 studies, not saved

“MEDIUM” search was completed and limited to studies First Received between 01/01/2006-12/22/2010:

( “attention deficit” OR “attention span” OR addh OR adhd OR “attention deficit and disruptive behavior disorders” OR “attention deficit disorder with hyperactivity” OR “behavior disorder” OR “behavior problems” OR “Child Behavior Disorders” OR “disruptive behavior” OR “disruptive disorder” OR distractability OR hyperactive OR hyperactivity OR hyperkinesia OR Hyperkinesis OR hyperkinetic OR “Impulse Control Disorders” OR “Impulsive Behavior” OR impulsiveness OR inattention OR inattentive OR “minimal brain dysfunction” OR “oppositional defiant disorder” ) [DISEASE] AND ( “01/01/2006” : “12/22/2010” ) [FIRST-RECEIVED-DATE]

= 611 studies, not saved

“FOCUSED” Results only about AHDH:

“attention deficit” OR “attention span” OR addh OR adhd OR “attention deficit and disruptive behavior disorders” OR “attention deficit disorder with hyperactivity” OR “child behavior disorders”

= 391 studies—saved as a zip (text) file

## VERSION 1—(Dec. 20, 2010)—Original Searches

### I ADHD search strings for RePORTER

“LARGE” search, inclusive of all ADHD terms used by McMaster

“aggression,aggressive behavior,aggressiveness,agonistic behavior,anger,attention deficit,attention span,addh,adhd,attention deficit and disruptive behavior disorders,attention deficit disorder with hyperactivity,behavior disorder,behavior problems,bullying,Child Behavior Disorders,conduct disorder,disruptive behavior,disruptive disorder,distractability,hostility,hyperactive,hyperactivity,hyperkinesia,Hyperkinesis,hyperkinetic,Impulse Control Disorders,Impulsive Behavior,impulsiveness,inattention,inattentive,minimal brain dysfunction,oppositional defiant disorder,self control”

=2392 results, not saved

“MEDIUM” Selected more specific ADHD terms

“attention deficit,attention span,addh,adhd,attention deficit and disruptive behavior disorders,attention deficit disorder with hyperactivity,behavior disorder,behavior problems,Child Behavior Disorders,disruptive behavior,disruptive disorder,distractability,hyperactive,hyperactivity,hyperkinesia,Hyperkinesis,hyperkinetic,Impulse Control Disorders,Impulsive Behavior,impulsiveness,inattention,inattentive,minimal brain dysfunction,oppositional defiant disorder”

=1487 results, not saved

“FOCUSED” Results only about AHDH:

“attention deficit,attention span,addh,adhd,attention deficit and disruptive behavior disorders,attention deficit disorder with hyperactivity”

=759 results—downloaded 100 per file, so that abstracts are included when present. For download files larger than 100 records, there are no abstracts included. This is the least “user-friendly” of the three databases searched.

### II ADHD search for HSRProj

aggression OR “aggressive behavior” OR aggressiveness OR “agonistic behavior” OR anger OR “attention deficit” OR “attention span” OR addh OR adhd OR “attention deficit and disruptive behavior disorders” OR “attention deficit disorder with hyperactivity” OR “behavior disorder” OR “behavior problems” OR bullying OR “Child Behavior Disorders” OR “conduct disorder” OR “disruptive behavior” OR “disruptive disorder” OR distractability OR hostility OR hyperactive OR hyperactivity OR hyperkinesia OR Hyperkinesis OR hyperkinetic OR “Impulse Control Disorders” OR “Impulsive Behavior” OR impulsiveness OR inattention OR inattentive OR “minimal brain dysfunction” OR “oppositional defiant disorder” OR “self control”

=199 projects saved in an EndNote library, kept

### III ClinicalTrials.gov

Expert Search of all fields:

Full “LARGE” search:

aggression OR “aggressive behavior” OR aggressiveness OR “agonistic behavior” OR anger OR “attention deficit” OR “attention span” OR addh OR adhd OR “attention deficit and disruptive behavior disorders” OR “attention deficit disorder with hyperactivity” OR “behavior disorder” OR “behavior problems” OR bullying OR “Child Behavior Disorders” OR “conduct disorder” OR “disruptive behavior” OR “disruptive disorder” OR distractability OR hostility OR hyperactive OR hyperactivity OR hyperkinesia OR Hyperkinesis OR hyperkinetic OR “Impulse Control Disorders” OR “Impulsive Behavior” OR impulsiveness OR inattention OR inattentive OR “minimal brain dysfunction” OR “oppositional defiant disorder” OR “self control”

=2463 studies, not saved

“FOCUSED” Results only about AHDH:

“attention deficit” OR “attention span” OR addh OR adhd OR “attention deficit and disruptive behavior disorders” OR “attention deficit disorder with hyperactivity”

= 582 studies—saved as a zip (text) file—later discarded