# Effective Health Care (EHC) Program Modified Selection Criteria^*^ * Modified to emphasize the three elements most applicable to stakeholders considering future research needs on a topic already under review by the EHC Program.

- Importance
  ◦ Represents a significant disease burden, large proportion, or priority population
  ◦ Is of high public interest; affects health care decisionmaking, outcomes, or costs for a large proportion of the U.S. population or for a priority population in particular
  ◦ Represent important uncertainty for decisionmakers
  ◦ Incorporates issues around both clinical benefits and potential clinical harms
  ◦ Represents important variation in clinical care, or controversy in what constitutes appropriate clinical care
  ◦ Represent high costs due to common use, to high unit costs, or to high associated costs to consumers, to patients, to health care systems, or to payers
- Desirability of new research/duplication
  ◦ Would not be redundant (the proposed gaps have not been sufficiently addressed by previous research)
- Potential Impact
  ◦ Potential for significant health impact, significant economic impact, potential change, potential risk from inaction, addressing inequities and vulnerable populations, and/or addressing a topic with clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups