# Web-Based Prioritization Exercises

Figure B-1 Prioritization Exercise 1

Figure B-2 Prioritization Exercise 2