# Research Gaps Identified From the Draft Comparative Effectiveness Review

(Draft report posted October 2010)

To generate the list below, content and methodological experts at the RTI-UNC Evidence-based Practice Center (EPC) reviewed the draft Comparative Effectiveness Review, Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-Risk Preschoolers; Long-Term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment, and produced a list of evidence gaps from the limitations and recommendations for future research sections in the report. The list was supplemented by identifying gaps mentioned in the report text that were not explicitly described in either of these sections. We wished to be inclusive at this stage of the future research needs process, providing the stakeholders with the full range of evidence gaps identified throughout the report. Minor rewording of the evidence gaps in the EPC report was conducted for consistency. The list below is in no particular order; the numbers are for reference only.

Preliminary list of evidence gaps from the draft review

Gap # | Evidence Gap
1 | Limited data are available about the relative efficacy of psychosocial and behavioral treatment programs (e.g., parent training compared with summer behavior treatment programs) for children less than 6 years old with disruptive behavior disorder or ADHD. (KQ 1)
2 | Limited data are available about the relative efficacy of psychosocial and behavioral treatment programs (e.g., parent training compared with summer behavior treatment programs) for children age 6 years or older with or ADHD. (KQ 2)
3 | There is a paucity of research among children less than 6 years of age with disruptive behavior disorder or ADHD examining positive child treatment results for variants on multimodal interventions (e.g., combinations of parent behavior training, summer behavior treatment programs, school-based interventions, or other cross-sectorial evaluations), and effects on specific subgroups. (KQ 1)
4 | There is a paucity of research among children ages 6 years or older with ADHD examining positive child treatment results for variants on multimodal interventions (e.g., combinations of parent behavior training, summer behavior treatment programs, school-based intervention), and effects on specific subgroups. (KQ 2)
5 | There are few efficacy studies on prescriptive treatments or optimal circumstances for adding specific psychosocial and/or pharmacological treatment components for preschoolers with disruptive behavior disorder or ADHD based on the child’s needs. (KQ 1)
6 | There are few efficacy studies on prescriptive treatments or optimal circumstances for adding specific psychosocial and/or pharmacological treatment components for children age 6 years and older with ADHD based on the child’s needs. (KQ 2)
7 | There is a paucity of studies among children less than 6 years old with disruptive behavior disorder or ADHD documenting adverse events or noncompliance rates for psychosocial interventions including parent training and school-based interventions. (KQ 1)
8 | There is a paucity of studies among children age 6 years or older with ADHD documenting adverse events or noncompliance rates for psychosocial interventions including parent training and school-based interventions. (KQ 2)
9 | There are limited data on the influence of parental preferences regarding treatment approaches or modes of service delivery on short- and long-term outcomes for children less than 6 years old. (KQ 1)
10 | There is a paucity of studies among children less than 6 years old with disruptive behavior disorder or ADHD that disassemble the key components of available psychosocial and behavioral treatment programs (e.g., specific parent training techniques compared to treatment components targeting the child and variants in service delivery to accommodate parental preferences). (KQ 1)
11 | Conflicting results from treatment studies of children less than 6 years old with disruptive behavior disorder or ADHD show improvements in ADHD symptoms when the parent behavior training protocol is adjusted and when the protocol is not adjusted. Studies comparing the relative efficacy among children less than 6 years old with disruptive behavior disorder or ADHD of specific adjustments to parent behavior training protocols are currently not available. (KQ 1)
12 | There are limited data available from studies with appropriate comparison groups about long-term outcomes for preschool interventions. (KQ 1)
13 | For people ages 6 years or older with ADHD, there are limited data available examining longer-term follow-up of psychosocial and pharmacological ADHD treatments with appropriate comparison groups for long-term outcomes including academic and educational outcomes. (KQ 2)
14 | There is a paucity of prospective combination pharmacological studies (e.g., combination pharmacotherapy treatment in ADHD [stimulants + antipsychotics, stimulants + alpha agents]) among people ages 6 years or older with ADHD as well as studies that follow individuals no longer requiring medication. (KQ 2)
15 | There is a paucity of studies among people with ADHD age 6 years or older that examine mediators and moderators of positive treatment response. The extant literature provides limited information about variations in treatment response by specific sociodemographic characteristics (e.g., low socioeconomic status, gender, different racial or ethnic groups) and baseline clinical indices (e.g., comorbidity with other psychiatric disorders, ADHD subtypes, comorbid developmental disorders, comorbid learning disabilities, language impairments, reading or mathematics disorders). (KQ 2)
16 | Standardized outcome measures such as global impairment scales or quality of life scales are needed to compare study outcomes from different cohorts of people with ADHD age 6 years and older. (KQ 2)
17 | Research among people with ADHD age 6 years and older that compares efficacy as measured by different data-capturing methods such as child self-rating scales, parent rating scales, and semistructured interviews is limited. (KQ 2)
18 | There is limited research on the impact of discrepancies between multiple informants (e.g., parent vs. child; parent vs. teacher; parent vs. clinician) on the effectiveness of treatments for people of all ages with ADHD. (KQ 2, 3)
19 | The extant literature lacks evidence-based performance measures for assessing prevalence and treatment outcomes for people of all ages with ADHD on a comparable metric. Standardized methods of data collection, case identification, and outcomes measurement in epidemiologic surveys and administrative databases are lacking, particularly for adolescents and adults. (KQ 3)
20 | Beyond randomized controlled trial protocols, there is limited research that examines patterns of service usage and factors that influence access and receipt of health services such as cross-sector coordination of health services, family and child factors, and availability of health insurance for people of all ages with ADHD. (KQ 3)