# Acknowledgments

The RTI International–University of North Carolina at Chapel Hill Evidence-based Practice Center (RTI–UNC EPC) would like to thank our stakeholder panel who gave generously of their time. Their expertise and enthusiasm helped drive this project. We would also like to thank our friends and colleagues, Lynda Booker, Alice Charach, Mary Gauld, and Pat Carson at the McMaster University EPC, authors of the 2010 draft AHRQ report. Thanks also to Mattias Johnson and Shannon Brode, from the University of North Carolina at Chapel Hill Cecil G. Sheps Center for Health Services Research, for their work in developing our online surveys; and Christiane Voisin, also from the Sheps Center, for library support. We also express our gratitude to RTI staff Loraine Monroe, Judy Cannada, and Susan Beck, Publications Specialists, and Laura Small, Editor.