# Abbreviations

ADD: attention deficit disorder
ADHD: attention deficit hyperactivity disorder
AHRQ: Agency for Healthcare Research and Quality
ATX: atomoxetine
CD: conduct disorder
CER: Comparative Effectiveness Review
CI: confidence interval
DEX: dextroamphetamine
DSM: Diagnostic and Statistical Manual
EHC: Effective Health Care
EPC: Evidence-based Practice Center
FRN: Future Research Need
ICTRP: International Clinical Trials Registry Project
KQ: Key Question
MAS: mixed amphetamphetamine salts
MIPD: Meta-analysis of Individual Participant Data
MPH: methylphenidate
MTA: Multimodal Treatment Study of Children with Attention Deficit Hyperactivity Disorder
N/A: not applicable
NCSH: National Survey of Child Health
ODD: oppositional defiant disorder
PBRNs: practice-based research networks
PICOTS: populations, interventions, comparators, outcomes, timeframes, and settings
RCT: randomized controlled trial
XR: extended release