# Results

## Recently Published and Ongoing Studies

The findings from our review of the recently published literature and ongoing studies are summarized in Appendix C.

The PubMed search updating the original CER identified 309 articles. These were reviewed, and 25 met our inclusion criteria. The majority of large studies reporting cardiovascular outcomes reported secondary outcomes or subgroup analyses from previously published large clinical trials.12,16–19 There was no recently published research for several of the research areas, including strategies to enhance greater evidence-based use, impact of ACE inhibitors or ARBs on quality of life, impact of ACE inhibitor/ARB adherence, and dose-response relationship between ACE inhibitors and ARBs. The largest number of recently published research focused on the outcomes of cardiovascular events (10 studies) and development of new diagnoses (6 studies). One large clinical trial published after the CER report found no impact of the ARB valsartan vs. placebo on cardiovascular outcomes.20

The search of Clinicaltrials.gov identified 207 registered trials, of which 60 were still open at the time of the search. From these, we included 25 studies based on our review criteria.

The search of PubMed for relevant systematic reviews identified 134 articles, of which only 3 were included after review. The majority of articles were excluded because they represented expert narrative reviews rather than systematic reviews to answer a particular research question.

## Recommended Research Prioritization

We describe here the findings of our three prioritization exercises. As described above, prioritization was designed as an iterative process with each successive exercise built on the previous exercise and its findings. Each step was followed by a conference call, during which stakeholders were provided with the prioritization results and had an opportunity to discuss the findings and the relative merits of each research priority. This process occurred in three distinct steps:

1. After compiling the list of potential future research areas, stakeholders were asked to:
  a. Rate the importance of each research area using a 5-point Likert scale
  b. Rank their top five priority research areas
2. Following review and discussion of these initial results, we asked individual stakeholders to rank all 16 research areas in order of importance.
3. We provided the stakeholders with an updated literature review of recent and ongoing research for each priority and presented a decision analytic model identifying areas of uncertainty in this field. Following this, we asked each stakeholder to re-rank all 16 research areas in order of importance.

### Prioritization Exercise 1

Table D1 (Appendix D) provides the Likert scale data for the first step in the research prioritization. Of note, this method of prioritization did not allow the 16 research areas to be broadly distributed in terms of importance and resulted in numerous areas receiving the same average score. Table D2 (Appendix D) lists the research areas grouped by average score.

Table D3 (Appendix D) demonstrates the results when stakeholders were asked to explicitly rank the top five research areas. Table D4 (Appendix D) summarizes these findings and when compared with Table D2 (Appendix D) demonstrates that the prioritization of these research areas differs depending on the prioritization method used.

### Prioritization Exercise 2

Our second prioritization exercise had individual stakeholders rank the 16 research areas in order of importance. Table D5 (Appendix D) provides the results of this ranking by stakeholder and then summary statistics of these rankings. Of note is that 14 of 16 research areas were ranked by at least one stakeholder as being in the top four research areas, while simultaneously being ranked by a second stakeholder as being in the bottom four research areas in terms of importance. Five of the research priorities (evidence-based use, comorbidities, adherence, cardiovascular outcomes, and class effect) were ranked by at least one stakeholder as being most important area for future research.

Table D6 (Appendix D) displays the prioritized list of research areas using the average rank score. The overall ranking of the list did not differ substantially when it was prioritized using the median score. Prioritizing based on the 1st quartile would have increased the importance of evaluating ACE inhibitor/ARB adherence (from a rank of 6th to 2nd).

### Prioritization Exercise 3

Our final prioritization exercise had stakeholders re-rank the research areas from 1 to 16 after reviewing the findings of the decision analytic model, discussing as a group the rankings from the second prioritization exercise, and reviewing the status of recently published and ongoing studies by research area (see Appendix C).

Table D7 (Appendix D) presents the individual rankings and summary statistics for this final prioritization exercise. Of note, most of the rankings remained consistent between the second and third exercises. Notable exceptions included the ranking of research into the incidence of new diagnoses (such as diabetes, atrial fibrillation, or CHF with or without preserved LV function), which fell from being ranked second to being ranked sixth. It was instead replaced by an emphasis on research into medication adherence. This change could potentially have been influenced by the relatively large number of recently published studied (n=6) and ongoing clinical trials (n=5) related to new diagnoses and the scarcity of research (no new studies, and one potentially relevant clinical trial) related to medication adherence. Of interest, the decision analytic model of ACE inhibitor and ARB therapy in IHD patients indicated that uncertainty related to new diagnoses had a significant impact on the model’s findings.

Although the overall ranking did not change substantially from the second to the third prioritization exercise, the consensus among the stakeholders in their rankings did improve. The variance in the rankings was greatly reduced, and although one stakeholder still ranked the top research area (evidence-based use) as 12th, there was much more consistency among the stakeholders and their rankings of the top and bottom five areas.

Table 2 lists the final prioritization of the 16 research areas using the average score from Prioritization Exercise 3. Gray shading indicates gaps identified by the stakeholders that were not part of the scope of the original CER.

Table 2 Final ranking of 16 research areas

Ranking | Research area
1 | Strategies to enhance greater evidence-based use of ACEIs/ARBs
2 | The impact of ACEI/ARB adherence (including differential adherence within and between medication classes) on their effectiveness or harms in patients with stable IHD
3 | Impact of comorbidities (such as hypertension, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single- vs. multi-vessel coronary artery disease) on ACEI/ARB effectiveness or harms in patients with stable IHD
4 | The impact of ACEI/ARB in patients with stable IHD on patient quality of life
5 | Impact of demographic differences (such as age, race, sex) on ACEI/ARB effectiveness or harms in patients with stable IHD
6 | The impact of ACEI/ARB in patients with stable IHD on incidence of new diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function)
7 | The benefit of ACEIs/ARBs relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms in patients with stable IHD
8 | The impact of ACEI/ARB in patients with stable IHD on utilization and cost of therapy
9 | The impact of ACEI/ARB in patients with stable IHD on cardiovascular outcomes (such as cardiovascular death, nonfatal MI, CVA, hospitalization for CHF, and surrogates such as blood pressure control, measures of atherosclerosis, etc.)
10 | Impact of concurrent medications (such as antiplatelet agents, lipid-lowering medications, other antihypertensives) on ACEI/ARB effectiveness or harms in patients with stable IHD
11 | The impact of ACEI/ARB in patients with stable IHD on progression of renal insufficiency or development of dialysis dependence
12 | Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACEI/ARB effectiveness or harms in patients with stable IHD
13 | Impact of the dose response (impact of medication dose or dosing interval) of ACEIs and ARBs on their effectiveness or harms in patients with stable IHD
14 | Impact of class effect (impact of differences between specific agents within each class) of ACEIs and ARBs on their effectiveness or harms in patients with stable IHD
15 | The impact of ACEI/ARB in patients with stable IHD on development of nonangioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia)
16 | The impact of ACEI/ARB in patients with stable IHD on development of angioedema

Abbreviations in Table 2: ACEI(s) = angiotensin-converting enzyme inhibitor(s), ARB(s) = angiotensin II receptor blocker(s)/antagonist(s), CHF = congestive heart failure, CVA = cerebrovascular accident, IHD = ischemic heart disease, LV = left ventricular, MI = myocardial infarction, PICO = population, interventions, comparators of interest, and outcomes

## Appropriate and Feasible Study Designs

Table 3 depicts our final ranked research areas and specific recommendations for addressing the 16 identified evidence gaps. For each potential research area, we provide our rationale for why each higher level of study design is not feasible or appropriate. The top six research areas were consistently ranked highly and deemed most important; these six areas are enclosed within broad borders for emphasis in Table 3. Again, those research areas that were outside the scope of the original CER are shaded in gray. While these gaps were clearly identified as important by the stakeholders, we have some caveats concerning recommended study designs. We did perform a literature search and a search of ongoing trials to identify duplication and assess feasibility; however our choice of study design is less well grounded for these gaps than for the other gaps which are backed up by a full systematic review

Table 3 Ranked research area prioritization and recommended study designs for addressing evidence gaps

Rank | Research area | RCT? | Meta-analysis of RCTs? | Meta-analysis of observational | New observational study? | Analysis of existing data? | Model?
1 | E: Strategies to enhance greater evidence-based use of ACEIs/ ARBs | Maybe: Need to consider whether issues related to evidence-based medication use are unique to ACEIs/ ARBs. In addition there may be technical issues with generalizability of RCT on practitioner behavior— practitioners willing to participate in RCT may be more likely to practice evidence-based medicine (EBM). | Maybe: If issues related to evidence-based practice are generic and sufficient studies on specific strategies available, meta-analysis might be feasible | Maybe: If issues related to evidence-based practice are generic, and sufficient studies on specific strategies are available, meta-analysis might be feasible. Technical issues with ability to adjust for wide range of potential confounders. | Maybe: If able to prospectively follow outcomes after implementation of new strategy for enhancing evidence-based use | Yes: Comparison of different settings with different incentives/ disincentives for evidence-based prescribing | Maybe: Potential role for modeling impact of different strategies, including use of newer techniques such as agent-based modeling. Could inform future study design.
2 | F: The impact of ACEI/ARB adherence (including differential adherence within and between medication classes) on their effectiveness or harms in patients with stable IHD | Maybe: If sufficient data on impact on nonadherence (e.g., difference in outcomes between ITT and adherent populations). Major limitation is that RCT subjects may not be generalizable to overall patient population. | Maybe: If additional evidence available was not previously included in the original CER and if sufficient data on impact on nonadherence (e.g., difference in outcomes between ITT and adherent populations). Major limitation is that RCT subjects may not be generalizable to overall patient population. | Maybe: If additional evidence available not previously included in the original CER and if data on adherence collected consistently across studies | Yes: Most reliable way to track adherence | Maybe: Technical issues with measuring adherence from administrative data | Maybe: Model could help determine clinically important differences
3 | A: Impact of comorbidities (such as hypertension, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single-vs. multi-vessel coronary artery disease) on ACEI/ARB effectiveness or harms in patients with stable IHD | Maybe: May be feasible for common comorbidities; existing or ongoing studies might be sufficient for some | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis. Analysis would require cooperation from the multiple sponsors of RCTs in this area. | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis. Would require cooperation from the multiple sponsors of RCTs in this area. If available, could address less common comorbidities, longer term safety/effectiveness | Maybe: Most direct way of addressing less common methods; allows for adjustment for confounding. Sample size and resources needed for longer followup are potential limitations. | Yes: Most efficient method for less common comorbidities over longer time frames. Appropriate coding of covariates a potential limitation. | No: Except for potential role in defining clinically or economically meaningful differences
4 | K: The impact of ACEI/ARB in patients with stable IHD on patient quality of life | Yes: Incorporation of disease-specific and generic QOL instruments into new trials | Maybe: If additional evidence available not previously included in the original CER with consistent use of instruments to allow data synthesis | No: Validated QOL instruments rarely reported in observational studies | Yes: Relatively low cost. Cross-sectional studies for obtaining population-level utilities reasonable. | Maybe: If validated QOL instrument collected | Maybe: Model could help determine clinically important differences
5 | B: Impact of demographic differences (such as age, race, sex) on ACEI/ARB effectiveness or harms in patients with stable IHD | No: Unlikely to be sufficient power in single RCT to determine differences among subgroups | Maybe: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis. Would likely require cooperation from the multiple sponsors to obtain unpublished information. | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis. Would likely require cooperation from the multiple sponsors to obtain unpublished information | Yes: If new data collection undertaken to address other questions, impact of demographic differences could be estimated in analysis | Yes: Most efficient method. Appropriate coding of other covariates a potential limitation. | Maybe: Model could help determine impact of subgroup differences on overall population effectiveness, cost-effectiveness
6 | J: The impact of ACEI/ARB in patients with stable IHD on incidence of new diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function) | No: Relatively large number of recent or ongoing studies; unclear what additional information new RCTs would provide | Yes: Sufficient number of studies. Main potential issue is duration of followup. | Yes: If available, could address less common outcomes over longer time frame | Maybe: Most direct way of addressing duration limitations; allows for adjustment for confounding. Sample size and resources needed for longer followup are potential limitations. | Yes: May be most efficient method, given resources needed for new study. Appropriate coding of covariates a potential limitation. | No: Except for potential role in defining clinically or economically meaningful differences
7 | I: The benefit of ACEIs/ARBs relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms in patients with stable IHD | Yes: Especially for shorter term outcomes | Yes: Especially for shorter term outcomes | Maybe: If sufficient number of studies available; adjustment for confounding an issue | Maybe: Most appropriate for longer term outcomes; resource requirements for longer term studies a major issue | Yes: Appropriate coding for covariates an issue | Yes: Model could help determine clinically important differences
8 | M: The impact of ACEI/ARB in patients with stable IHD on utilization and cost of therapy | Maybe: Could collect cost/ utilization data as part of RCT; major issue is generalizability | Maybe: If sufficient number of studies available | Maybe: If sufficient number of studies available | Maybe: Adding costs/utilization to planned observational study reasonable | Yes: Appropriate coding for covariates an issue | Yes: Model helpful for determining meaningful differences
9 | L: The impact of ACEI/ARB in patients with stable IHD on cardiovascular outcomes (such as cardiovascular death, nonfatal MI, CVA, hospitalization for CHF, and surrogates such as blood pressure control, measures of atherosclerosis, etc.) | Maybe: Large number of studies recently completed or ongoing | Maybe: if additional evidence available not previously included in the original CER s | Maybe: If sufficient number of studies available; adjustment for confounding an issue | Maybe: Most appropriate for longer term outcomes; resource requirements for longer term studies a major issue | Yes: Appropriate coding for covariates an issue | Maybe: Model could help determine clinically important differences
10 | C: Impact of concurrent medications (such as antiplatelet agents, lipid-lowering medications, other antihypertensives) on ACEI/ARB effectiveness or harms in patients with stable IHD | No: Unlikely to be sufficient power within single trial | Maybe: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis. Would likely require cooperation from the multiple sponsors to obtain unpublished information. | Maybe: If individual patient data or separate subgroup data not reported in current studies could be obtained and pooled for analysis. Would likely require cooperation from the multiple sponsors to obtain unpublished information. | Yes: May be required for longer term outcomes | Yes: Appropriate coding for covariates an issue | Maybe: Model could help determine clinically meaningful differences
11 | N: The impact of ACEI/ARB in patients with stable IHD on progression of renal insufficiency or development of dialysis dependence | Maybe: If existing or ongoing studies unlikely to answer question | Yes: Likely to be sufficient number of studies | Maybe: If sufficient number of studies available | Yes: May be required for longer term outcomes | Yes: Appropriate coding for covariates an issue | Maybe: Model could help determine clinically meaningful differences
12 | D: Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACEI/ARB effectiveness or harms in patients with stable IHD | Maybe: Sample size is major issue | Maybe: If sufficient number of studies. Patient-level meta-analysis of RCT data would be particularly useful. | Maybe: If sufficient number of studies | Yes: Most feasible way to ensure that genetic material available | Maybe: If genetic data available, or reasonable options for obtaining | Yes: Model could help determine potential clinical utility of identifying genetic differences
13 | G: Impact of the dose response (impact of medication dose or dosing interval) of ACEI and ARBs on their effectiveness or harms in patients with stable IHD | Yes: Most straightforward way to obtain estimate of impact on different dosing | Maybe: If sufficient number of studies | No: Dose response difficult to measure in observational data | No: Dose response difficult to measure in observational data | No: Dose response difficult to measure in observational data | Maybe: Model could be useful for determining clinically meaningful differences
14 | H: Impact of class effect (impact of differences between specific agents within each class) of ACEI and ARBs on their effectiveness or harms in patients with stable IHD | Yes: Ideal for unbiased estimate; if equivalence study, could require large sample size | Maybe: If sufficient number of studies | Maybe: If sufficient number of studies | Maybe: RCT would be preferable | Maybe: RCT would be preferable; appropriate coding for covariates is an issue. Could be useful for preliminary estimates. | Maybe: Model could be useful for determining clinically meaningful differences
15 | O: The impact of ACEI/ARB in patients with stable IHD on development of nonangioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia) | No: Reasonable number of studies, power of individual studies limited | Maybe: If additional evidence available not previously included in the original CER | Maybe: If additional evidence available not included in the original CER. | Maybe: Observational design more practical for longer term outcomes | Maybe: Coding of covariates main issue | Maybe: Model potentially useful for determining clinically meaningful differences
16 | P: The impact of ACEI/ARB in patients with stable IHD on development of angioedema | No: Reasonable number of studies, power of individual studies limited | Maybe: If additional evidence available not previously included in the original CER. | Maybe: if additional evidence available not previously included in the original CER | Maybe: Observational design more practical for longer term outcomes | Maybe: Coding of covariates main issue | Maybe: Model potentially useful for determining clinically meaningful differences

Abbreviations in Table 3: ACEI(s) = angiotensin-converting enzyme inhibitor(s), ARB(s) = angiotensin II receptor blocker(s)/antagonist(s), CHF = congestive heart failure, CVA = cerebrovascular accident, IHD = ischemic heart disease, ITT = intention-to-treat, LV = left ventricular, MI = myocardial infarction, PICO = population, interventions, comparators of interest, and outcomes, QOL = quality of life