# Methods

## Identifying Ongoing Studies

We performed three database searches to identify ongoing and recently published studies relevant to the identified evidence gaps. These searches included the following:

1. A search of ClinicalTrials.gov for ongoing studies.
2. An update (via PubMed^®^) of the MEDLINE^®^ search used in the original CER, “Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease,”10 and the associated Annals of Internal Medicine publication11 to identify relevant randomized controlled trial (RCT) literature published since the last search date (July 2009).
3. A search of PubMed for relevant systematic reviews and meta-analyses published since July 2009.

The exact search strategies used are provided in Appendix A.

Search results were reviewed for applicability to the identified research gaps listed in Table 1. We included articles from each search if they met the following criteria: (1) included patients with known IHD or at high risk for IHD based on risk factors of hypertension, diabetes, peripheral arterial disease, or chronic kidney disease, but excluding congestive heart failure (CHF); (2) reported original data or combined original data in a systematic review or decision analysis; (3) included a comparison between either an ACE inhibitor or ARB and either an alternative medication, another ACE inhibitor or ARB, or placebo; and (4) included outcomes that could be categorized according our identified list of research priorities.

## Prioritizing Research

We used multiple methods to prioritize the identified research needs. These included both a qualitative prioritization exercise and then further ranking of the research areas after a quantitative ranking of the areas using a decision analytic framework. A more formal comparison of these different methods (specifically, a comparison of the qualitative and quantitative processes) will be discussed in our upcoming report on “Future Research Methods Project: Determining Appropriate Use of Modeling or Value of Information.” In the present pilot report we instead describe the prioritization tools and process, but then focus on the findings as they specifically relate to the evidence gaps in the comparative effectiveness of ACE inhibitor and ARB therapy in patients with IHD.

Participants in our stakeholder group (described below) participated in three prioritization exercises and three conference calls. Each prioritization exercise included a group discussion of the previous exercise’s findings and built on the previous exercise’s ranking of research areas. The ranking from the third prioritization exercise was therefore considered to be cumulative and to represent the final order of research areas. The results of each prioritization exercise are summarized in Appendix D.

The first conference call (June 2010) was used to introduce the stakeholder group to the project’s objective and to describe the key clinical questions, the original CER report and its findings, and proposed methods for the prioritization process, including the use of a decision model and value-of-information analyses to quantitatively prioritize the research needs. Stakeholders were then asked to rate the importance of further research exploring various characteristics using a 5-point Likert scale via an online tool (Appendix B). They were also asked to rank their top five research priorities from the complete list. We used these two ranking exercises to look for internal consistency by individual stakeholders in their ranking and to help us identify any confusion with the prioritization exercise.

Stakeholders then participated in a second conference call (July 2010), in which the results of the initial exercise were reviewed with the group and discussed. During this conference call it became clear to the Duke EPC investigative team that several components of the exercise needed to be clarified—both in terms of the criteria the stakeholders should be considering when prioritizing research needs, and the current evidence base of the comparative effectiveness of ACE inhibitor and ARB therapy in patients with IHD.

Although we had planned only one prioritization exercise using the qualitative survey, based on our second conference call and the need for clarification, we distributed to the stakeholder group additional material (Appendix B) including a list of potential priority setting criteria that could be used when considering the appropriate priority for the research questions, the results of the initial survey prioritization, and summary evidence tables from the original CER report and resulting publication. We then asked each stakeholder to rank the 16 research areas from 1 to 16 in order of importance. The final conference call (September 2010, Appendix B) reviewed the findings of the second prioritization exercise, detailed the Duke EPC’s search of recently published literature and ongoing trials, described the decision analytic model and its key assumptions and data, discussed the model’s findings, and, finally, provided an opportunity for the group to discuss the existing ranking. As planned a priori, this final conference call focused on the quantitative findings from the decision analytic model. After this call, a final survey was distributed to the stakeholder group (Appendix B) that included the qualitative ranking results and the recently published literature and ongoing trials in each research area. Stakeholders were again asked to rank the areas from 1 to 16. This final exercise produced our final ranking.

## Determining Appropriate and Feasible Study Designs

In addition to exploring the prioritization of research needs, we sought to determine appropriate and feasible study designs for the identified priorities. Our overall approach to recommending specific study designs for addressing specific evidence gaps is depicted in Figure 3. In an ideal world, an effectiveness randomized controlled trial (RCT) would be conducted to address evidence gaps, since this design has the least risk of bias. However, for many evidence gaps, RCTs are not feasible for a variety of reasons, including the need for large sample sizes to adequately power for a representative population, the need for long duration of followup for some long-term outcomes, patient and provider reluctance to participate, and a variety of other factors. Our overall approach to study design recommendation starts with the premise that one should choose the least biased design that is feasible and affordable. If, for example, an RCT is not feasible, then a meta-analysis of RCTs (or a patient-level meta-analysis from RCTs) may be most appropriate and feasible. If meta-analysis of RCTs is not feasible, then meta-analysis (again, including patient-level analysis) of observational studies could provide valuable information to answer the research question. This somewhat hierarchical approach considers the feasibility and validity of the study to answer the question and assumes that the question is not answered by current research. However, questions that were identified as gaps in a systematic review presumably may not have sufficient evidence for a meta-analysis, although an individual patient data meta-analysis may still be valuable. For questions that were out of scope of the original systematic review, it may be appropriate to consider a systematic review to identify if trials or observational studies have already been conducted.

Figure 3 Flowchart of considerations for determining recommended and feasible study designs

Figure 3 is a representation of the process used for making recommendations for specific study designs. In general, the study design with the least risk of bias that can also feasibly address specific questions of interest is preferred. Starting with randomized controlled trials (RCTs), the applicability of a particular study design is considered in the context of a specific evidence gap until a reasonable balance is struck between risk of bias and practicality. In decreasing order of preference, study designs considered include RCTs, meta-analyses of RCTs, meta-analyses of observational studies, new observational studies specifically designed to address the evidence gap, analysis of existing observational data, and modeling studies. In some cases, modeling studies can be used to inform the design and evaluation of other study designs.

We explore below in more detail the potential study designs represented in Figure 3 and their specific considerations.

### Randomized Controlled Trials (RCTs)

Ideally, all evidence gaps would be filled by conducting effectiveness RCTs that specifically address the area of interest. However, especially for many questions of interest for comparative effectiveness research, RCTs are rarely the most practical option. Considerations include:

- Sample size required for a particular outcome and to include a representative sample of patients: Many outcomes of interest, particularly those involving safety, are relatively uncommon, requiring an inordinately large sample size to achieve adequate power.
- Size of the pool of potential subjects: Some conditions may be relatively uncommon, or the subpopulation of interest relatively small, adversely affecting the sample size. Alternatively, comorbidities may be common among patients with the condition in question, creating potential difficulties with inclusion/exclusion criteria for an RCT.
- Duration of followup required: Minimizing loss to followup within the context of a trial, particularly if blinding must be maintained, is both expensive and difficult the longer the duration of followup, but for some outcomes lengthy followup is required.
- Issues with willingness to be randomized: Patient and provider beliefs about effectiveness, side effects, or other factors can make it difficult to recruit subjects into trials for some interventions; for example, RCTs of treatments for conditions where hysterectomy is a potential therapy have historically had extreme difficulty meeting recruitment goals.
- Generalizability: Inclusion/exclusion criteria often mean that subjects who participate in RCTs rarely reflect the full spectrum of either disease severity or comorbidity that exist in the real world.

### Meta-Analysis of RCTs

If a new RCT is not feasible, then a meta-analysis of existing RCTs may provide the next most valid answer to the question if studies are available. However, all of the potential difficulties with a new RCT are potential problems with existing RCTs. Given sufficient numbers and quality of existing RCTs, some questions may be addressable through meta-analysis. The main issue is whether data on the variables and outcomes of interest have been collected and reported consistently by enough RCTs to warrant a meta-analysis.

Meta-analysis of RCTs may be particularly appropriate for research gaps outside the scope of the initial CER; however, as highlighted by the authors of the original CER in their discussion of future research needs, this method may also be able answer key questions included in the original CER. Depending on the volume of ongoing research, existing reviews may quickly become out of date, particularly in cardiovascular research.15 In addition, when insufficient evidence exists for particular key questions, modifying the study inclusion/exclusion criteria from the initial review may allow broader inclusion of studies that can address these research gaps. This may be particularly true when a specific clinical condition, such as IHD, has significant clinical overlap with related conditions such as hypertension, peripheral vascular disease, diabetes, chronic kidney disease, or congestive heart failure. When the outcomes of interest are common to all conditions (e.g., medication side effects, quality of life) then meta-analysis across clinical conditions may provide additional useful information.

In meta-analyses of clinical trials, clinicians are often interested in examining subset effects. However, study-level analyses, such as those conducted for the recent CER report of ACE inhibitors and ARBs by the University of Connecticut EPC, can lead to biased assessments and have some limitations in explaining heterogeneity. A meta-analysis of individual patient data offers several advantages for this purpose, but may not always be feasible given the multiple different sources of data and the proprietary nature of industry-sponsored research.

### Meta-Analysis of Observational Studies

If a meta-analysis of RCTs is not feasible, the next most valid and feasible alternative would be a meta-analysis of observational studies. Many of the same issues inherent in meta-analyses of RCTs (both study-level and patient-level data) are also present, including:

- Heterogeneity in study design, inclusion, and exclusion criteria;
- Consistency in variable definitions and collection; and
- Varying duration of followup.

In addition, control of confounding can be especially challenging at the study level. Here, patient-level meta-analysis may be particularly appropriate, since it facilitates adjustment. The main challenge here is accessibility to the appropriate data, which may be difficult, especially with industry-sponsored studies.

### Observational Study: Collection of New Data

If there is not sufficient literature available for a meta-analysis of observational data, then design of a new study would be the next most valid and feasible study design. Ideally, a prospective study with subject recruitment, data collection, and data analysis specifically intended to address the question of interest would be designed and carried out. Challenges to feasibility of a new observational study include:

- Duration of followup and retention: Many of the most important evidence gaps may require data on outcomes over a longer period of time. Subject retention is crucial both to maximize study power and minimize bias to differential dropout, but the resources required to maintain high retention over a long study period are substantial.
- Recruitment: Depending on the outcomes being assessed, participation in an ongoing observational study may be burdensome. Especially for patients treated with already approved treatments and whose clinical care is not affected by participation in a study, assuring maximal recruitment can be difficult. This may be a special problem in some populations with historically low levels of participation in research.

### Observational Study: Analysis of Existing Data

If a new observational study is not feasible, there may be existing data available that address the relevant question. Major issues here include:

- Ease of access to data, particularly proprietary data from industry-sponsored trials or private health plans
- Extracting useful data from administrative or clinical records. ICD-9 (International Classification of Diseases, Ninth Revision) and CPT (Current Procedural Terminology) codes are not sensitive to many relevant factors in a patient’s clinical history, or to disease severity within conditions. Paper records are difficult to abstract because of issues relating to legibility, consistency in diagnostic language, and the human resources required to convert clinical records into useful analytic data. Electronic medical records are more useful, but are not universally used, and systems may not be compatible. For any of these sources, data on the variables of greatest interest may not have been consistently collected.
- Generalizability: Patients enrolled in Medicare, Medicaid, or private health plans may differ in a number of respects, such as income and employment history, that may be relevant but which may be difficult to adjust for given the available data.

### Modeling

Finally, if none of the above options is feasible, simulation modeling may be able to address some questions. Modeling is particularly helpful for addressing questions that involve very long durations of followup, or options that cannot feasibly be included in an RCT, such as the comparative impact of different screening frequencies on cancer incidence, mortality, and life expectancy. The main limitation here is the availability of appropriate expertise in both modeling and the clinical conditions being studied. We provide an example of one use of modeling here; more detailed discussions of the potential uses for models in addressing evidence gaps will be included in upcoming reports both by our group and by other EPCs.

As an example of determining the recommended study design for a given evidence gap, we describe here the process we used for the gap exploring the impact of demographic differences (such as age, race, sex) on ACEI/ARB effectiveness or harms in patients with stable IHD. We first considered whether an RCT would be feasible. Unfortunately, it was determined that an ECT would be unlikely to have sufficient power in a single RCT to determine differences among subgroups and therefore would not be recommended. We next considered if a meta-analysis of RCTs would be feasible. We classified this study design as being possible but dependent on individual patient data or separate subgroup data not reported in current trials being obtained from the original authors and pooled for analysis. Such a meta-analysis of RCT data would likely require cooperation from the multiple sponsors to obtain unpublished information. The use of a meta-analysis of observational studies was believed to be more feasible though still most likely has the requirements of obtaining the needed data from multiple sponsors. Obtaining new data through an observational study was considered feasible. If new data collection was undertaken to address other questions, the impact of demographic differences could be estimated in the analysis. We felt that the most efficient method for exploring this evidence gap would be an observational study using existing data. Appropriate coding of other covariates is a potential limitation. Finally, modeling could help determine the impact of subgroup differences on overall population effectiveness or cost-effectiveness.

## Engaging Stakeholders, Researchers, and Funders

The authors developed this working document with input from a group of interested stakeholders. Nine stakeholders were selected for participation in this project from a variety of backgrounds and perspectives. The group included physicians affiliated with academic institutions, representatives of professional societies with a cardiovascular focus or expertise in comparative effectiveness research (American Heart Association, American College of Cardiology, American College of Physicians, Society for Medical Decision Making), a payer institution, industry representatives, the National Heart Lung and Blood Institute, and a patient representative.

Input was solicited from the stakeholders in reviewing and developing the list of research gaps, reviewing the structure of the decision analytic model, informing model assumptions and sources for data inputs, and identifying important outcomes for consideration in modeling. Once the list of research gaps was established, stakeholders were asked to participate in the three prioritization exercises described above.

Stakeholder input was solicited and received through web- and paper-based survey techniques, email, and group discussions via teleconference. Group discussions were moderated by the EPC investigators to avoid domination of the discussion by any particular group and to ensure that all participants had an equal opportunity to ask questions and express their views. The AHRQ Task Order Officer was a participant in all group teleconferences and was included on all electronic communication with the stakeholder group.

## Handling Conflicts of Interest

In selecting members of the stakeholder group, efforts were made to assemble a balanced group of individuals representing a range of perspectives. The group included individuals with experience in cardiology, as well as individuals with expertise in decision modeling and comparative effectiveness research.

Efforts were also made to avoid inclusion of researchers whose participation in the prioritization process might result in an unfair advantage in the development of future research proposals. Stakeholders were provided with the results of the first two qualitative prioritization exercises during the course of their participation in the project. The final recommended list of prioritized areas incorporating the final ranking of future research needs were not made available to the stakeholder group until public posting of the draft report.