# Executive Summary

The Effective Health Care Program was initiated in 2005 to provide valid evidence about the comparative effectiveness of different medical interventions. The object is to help consumers, health care providers, and others in making informed choices among treatment alternatives. Through its comparative effectiveness reviews, the program supports systematic appraisals of existing scientific evidence regarding treatments for high-priority health conditions. It also promotes and generates new scientific evidence by identifying gaps in existing scientific evidence and supporting new research. The program puts special emphasis on translating findings into a variety of useful formats for different stakeholders, including consumers.

The full report and this summary are available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.

## Background

Despite advances in therapy, ischemic heart disease (IHD) remains the most common cause of morbidity and mortality in the United States. Angiotensin-converting enzyme inhibitors (ACEIs) and angiotensin-II receptor blockers/antagonists (ARBs) have been shown to improve clinical outcomes for some patients, including those with heart failure and those with both myocardial infarction and ventricular dysfunction. However, the comparative effectiveness of ACE inhibitors and ARBs alone or in combination for patients with IHD remains uncertain.

A comparative effectiveness review (CER) published by the University of Connecticut Evidence-based Practice Center (EPC) in 2009 found strong evidence that ACE inhibitors reduced total mortality and nonfatal myocardial infarction (MI) in comparison to placebo among adults with stable IHD and preserved ventricular function, but increased the risk for syncope and cough. There was low to moderate evidence that ARBs reduced a composite of cardiovascular endpoints compared to placebo, and these agents were well-tolerated. The one available study directly comparing the impact of ACE inhibitors and ARBs on cardiovascular outcomes in patients with IHD revealed no significant difference between the classes in the rate of cardiovascular outcomes, but demonstrated higher rates of cough and angioedema among patients treated with ACE inhibitors, and higher rates of hypotensive symptoms among patients treated with ARBs.

A list of research gaps is a common component of CERs and is an important step in outlining a future research agenda; however, such lists do not always clearly suggest how future research should be prioritized, or which projects are in fact feasible. In this pilot project, we sought to expand on the work done by the University of Connecticut EPC to identify and prioritize gaps in the evidence supporting the comparative effectiveness of ACE inhibitor and ARB therapy in patients with IHD. The prioritization process we used combined a review of recently published and ongoing studies, engagement of nine stakeholders, and participation of these stakeholders in both qualitative and quantitative exercises of research needs prioritization.

## Methods

As part of the pilot project we (1) expanded the list of categories for possible future research based on discussions with the University of Connecticut EPC and review of a related CER on ACE inhibitors and ARBs for hypertension, (2) reviewed recently published and ongoing studies relevant to ACE inhibitor and ARB therapy in IHD, (3) performed three prioritization exercises with a group of nine stakeholders, and (4) developed a conceptual framework for recommending study designs.

## Ongoing Studies

To identify ongoing and recently published studies relevant to the identified evidence gaps we performed three searches. These searches included the following:

1. A search of ClinicalTrials.gov for ongoing studies.
2. An update (via PubMed^®^) of the MEDLINE^®^ search used in the original CER to identify relevant randomized clinical trial literature published since the last search date (July 2009).
3. A search of PubMed for relevant systematic reviews and meta-analyses published since July 2009.

## Research Area Prioritization

Project stakeholders participated in three conference calls and three prioritization exercises. Each prioritization exercise built off the findings of the previous exercise. The call and prioritization exercises occurred in the following order:

- Conference Call 1: Introduced stakeholders to the project’s objectives and described the key clinical questions, the original CER report and its findings, and proposed methods for the prioritization process, including use of a decision model and value-of-information analyses to quantitatively prioritize future research needs.
- Prioritization Exercise 1: Stakeholders were asked to rate the importance of future research exploring various characteristics using a five-point Likert scale via an online tool. They were also asked to rank their top five research priorities from the complete list.
- Conference Call 2: Used to review and discuss the results of the initial exercise.
- Prioritization Exercise 2: We distributed additional material to stakeholders, including a list of potential priority setting criteria to use when considering the appropriate priority for the research questions, the results of the initial survey prioritization, and summary evidence tables from the original CER report. Each stakeholder was then asked to rank the 16 research areas from 1 to 16 in order of importance.
- Conference Call 3: Reviewed the findings of the second prioritization exercise, detailed our search of recently published literature and ongoing trials, described the decision analytic model and its key assumptions and data, discussed the model’s findings, and then provided an opportunity for the group to discuss the existing ranking.
- Prioritization Exercise 3: Further material was distributed to stakeholders, including the qualitative ranking results and the recently published literature and ongoing trials in each research area. Each stakeholder was then asked to rank the areas from 1 to 16. This final step produced our final ranking.

## Study Design Recommendations

We developed a conceptual framework for recommending study designs. Our overall approach to recommending specific study designs for addressing specific evidence gaps emphasized the study design with the least risk of bias and the greatest likelihood of completion. For areas out of scope of the original CER, we suggest specific study designs that may be appropriate, although without the benefit of a comprehensive systematic review, cannot ascertain whether some of these studies have already been completed.

## Stakeholder Engagement and Handling Conflicts of Interest

Nine stakeholders were selected for participation in this project from a variety of backgrounds and perspectives. They included physicians affiliated with academic institutions, representatives of professional societies with a cardiovascular focus or expertise in comparative effectiveness research, a payer institution, industry representatives, the National Heart Lung and Blood Institute, and a patient representative. In selecting members of the stakeholder group, efforts were made to assemble a balanced group of individuals representing a range of perspectives. Efforts were also made to avoid inclusion of researchers whose participation in the prioritization process might result in an unfair advantage in the development of future research proposals.

## Results

Table A describes the final prioritized list of research areas with recommended study designs. The top six research areas were consistently ranked highly and deemed most important; these six areas are enclosed within broad borders for emphasis in Table A. As described in our methods, we expanded the list of research gaps to include five areas outside the scope of the original CER but deemed to be of high priority based on discussions with the University of Connecticut EPC team, our related work on the comparative effectiveness of ACE inhibitors and ARBs in patients with essential hypertension, and feedback from our stakeholders. These additional five research areas from outside the scope of the original CER are shaded in gray in Table A. For these five gaps identified as important by the stakeholders, we did perform a literature search and a search of ongoing trials to identify duplication and assess feasibility; however without a comprehensive systematic review, we cannot be certain that some of these studies have not already been done.

Table A Ranked research area prioritization and recommended study designs for addressing evidence gaps

Rank | Research area | RCT? | Meta-analysis of RCTs? | Meta-analysis of observational studies? | New observational study? | Analysis of existing data? | Model?
1 | E: Strategies to enhance greater evidence-based use of ACEIs/ARBs | Maybe: Need to consider whether issues related to evidence-based medication use are unique to ACEIs/ ARBs. In addition there may be technical issues with generalizability of RCT on practitioner behavior— practitioners willing to participate in RCT may be more likely to practice evidence-based medicine (EBM). | Maybe: If issues related to evidence-based practice are generic and sufficient studies on specific strategies available, meta-analysis might be feasible | Maybe: If issues related to evidence-based practice are generic, and sufficient studies on specific strategies are available, meta-analysis might be feasible. Technical issues with ability to adjust for wide range of potential confounders. | Maybe: If able to prospectively follow outcomes after implementation of new strategy for enhancing evidence-based use | Yes: Comparison of different settings with different incentives/ disincentives for evidence-based prescribing | Maybe: Potential role for modeling impact of different strategies, including use of newer techniques such as agent-based modeling. Could inform future study design.
2 | F: The impact of ACEI/ARB adherence (including differential adherence within and between medication classes) on their effectiveness or harms in patients with stable IHD | Maybe: If sufficient data on impact on nonadherence (e.g., difference in outcomes between ITT and adherent populations). Major limitation is that RCT subjects may not be generalizable to overall patient population. | Maybe: If additional evidence available was not previously included in the original CER and if sufficient data on impact on nonadherence (e.g., difference in outcomes between ITT and adherent populations). Major limitation is that RCT subjects may not be generalizable to overall patient population. | Maybe: If additional evidence available not previously included in the original CER and if data on adherence collected consistently across studies | Yes: Most reliable way to track adherence | Maybe: Technical issues with measuring adherence from administrative data | Maybe: Model could help determine clinically important differences
3 | A: Impact of comorbidities (such as hypertension, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single-vs. multi-vessel coronary artery disease) on ACEI/ARB effectiveness or harms in patients with stable IHD | Maybe: May be feasible for common comorbidities; existing or ongoing studies might be sufficient for some | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis. Analysis would require cooperation from the multiple sponsors of RCTs in this area. | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis. Would require cooperation from the multiple sponsors of RCTs in this area. If available, could address less common comorbidities, longer term safety/effectiveness | Maybe: Most direct way of addressing less common methods; allows for adjustment for confounding. Sample size and resources needed for longer followup are potential limitations. | Yes: Most efficient method for less common comorbidities over longer time frames. Appropriate coding of covariates a potential limitation. | No: Except for potential role in defining clinically or economically meaningful differences
4 | K: The impact of ACEI/ARB in patients with stable IHD on patient quality of life | Yes: Incorporation of disease-specific and generic QOL instruments into new trials | Maybe: If additional evidence available not previously included in the original CER with consistent use of instruments to allow data synthesis | No: Validated QOL instruments rarely reported in observational studies | Yes: Relatively low cost. Cross-sectional studies for obtaining population-level utilities reasonable. | Maybe: If validated QOL instrument collected | Maybe: Model could help determine clinically important differences
5 | B: Impact of demographic differences (such as age, race, sex) on ACEI/ARB effectiveness or harms in patients with stable IHD | No: Unlikely to be sufficient power in single RCT to determine differences among subgroups | Maybe: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis. Would likely require cooperation from the multiple sponsors to obtain unpublished information. | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis. Would likely require cooperation from the multiple sponsors to obtain unpublished information | Yes: If new data collection undertaken to address other questions, impact of demographic differences could be estimated in analysis | Yes: Most efficient method. Appropriate coding of other covariates a potential limitation. | Maybe: Model could help determine impact of subgroup differences on overall population effectiveness, cost-effectiveness
6 | J: The impact of ACEI/ARB in patients with stable IHD on incidence of new diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function) | No: Relatively large number of recent or ongoing studies; unclear what additional information new RCTs would provide | Yes: Sufficient number of studies. Main potential issue is duration of followup. | Yes: If available, could address less common outcomes over longer time frame | Maybe: Most direct way of addressing duration limitations; allows for adjustment for confounding. Sample size and resources needed for longer followup are potential limitations. | Yes: May be most efficient method, given resources needed for new study. Appropriate coding of covariates a potential limitation. | No: Except for potential role in defining clinically or economically meaningful differences
7 | I: The benefit of ACEIs/ARBs relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms in patients with stable IHD | Yes: Especially for shorter term outcomes | Yes: Especially for shorter term outcomes | Maybe: If sufficient number of studies available; adjustment for confounding an issue | Maybe: Most appropriate for longer term outcomes; resource requirements for longer term studies a major issue | Yes: Appropriate coding for covariates an issue | Yes: Model could help determine clinically important differences
8 | M: The impact of ACEI/ARB in patients with stable IHD on utilization and cost of therapy | Maybe: Could collect cost/ utilization data as part of RCT; major issue is generalizability | Maybe: If sufficient number of studies available | Maybe: If sufficient number of studies available | Maybe: Adding costs/utilization to planned observational study reasonable | Yes: Appropriate coding for covariates an issue | Yes: Model helpful for determining meaningful differences
9 | L: The impact of ACEI/ARB in patients with stable IHD on cardiovascular outcomes (such as cardiovascular death, nonfatal MI, CVA, hospitalization for CHF, and surrogates such as blood pressure control, measures of atherosclerosis, etc.) | Maybe: Large number of studies recently completed or ongoing | Maybe: if additional evidence available not previously included in the original CER s | Maybe: If sufficient number of studies available; adjustment for confounding an issue | Maybe: Most appropriate for longer term outcomes; resource requirements for longer term studies a major issue | Yes: Appropriate coding for covariates an issue | Maybe: Model could help determine clinically important differences
10 | C: Impact of concurrent medications (such as antiplatelet agents, lipid-lowering medications, other antihypertensives) on ACEI/ARB effectiveness or harms in patients with stable IHD | No: Unlikely to be sufficient power within single trial | Maybe: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis. Would likely require cooperation from the multiple sponsors to obtain unpublished information. | Maybe: If individual patient data or separate subgroup data not reported in current studies could be obtained and pooled for analysis. Would likely require cooperation from the multiple sponsors to obtain unpublished information. | Yes: May be required for longer term outcomes | Yes: Appropriate coding for covariates an issue | Maybe: Model could help determine clinically meaningful differences
11 | N: The impact of ACEI/ARB in patients with stable IHD on progression of renal insufficiency or development of dialysis dependence | Maybe: If existing or ongoing studies unlikely to answer question | Yes: Likely to be sufficient number of studies | Maybe: If sufficient number of studies available | Yes: May be required for longer term outcomes | Yes: Appropriate coding for covariates an issue | Maybe: Model could help determine clinically meaningful differences
12 | D: Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACEI/ARB effectiveness or harms in patients with stable IHD | Maybe: Sample size is major issue | Maybe: If sufficient number of studies. Patient-level meta-analysis of RCT data would be particularly useful. | Maybe: If sufficient number of studies | Yes: Most feasible way to ensure that genetic material available | Maybe: If genetic data available, or reasonable options for obtaining | Yes: Model could help determine potential clinical utility of identifying genetic differences
13 | G: Impact of the dose response (impact of medication dose or dosing interval) of ACEI and ARBs on their effectiveness or harms in patients with stable IHD | Yes: Most straightforward way to obtain estimate of impact on different dosing | Maybe: If sufficient number of studies | No: Dose response difficult to measure in observational data | No: Dose response difficult to measure in observational data | No: Dose response difficult to measure in observational data | Maybe: Model could be useful for determining clinically meaningful differences
14 | H: Impact of class effect (impact of differences between specific agents within each class) of ACEI and ARBs on their effectiveness or harms in patients with stable IHD | Yes: Ideal for unbiased estimate; if equivalence study, could require large sample size | Maybe: If sufficient number of studies | Maybe: If sufficient number of studies | Maybe: RCT would be preferable | Maybe: RCT would be preferable; appropriate coding for covariates is an issue. Could be useful for preliminary estimates. | Maybe: Model could be useful for determining clinically meaningful differences
15 | O: The impact of ACEI/ARB in patients with stable IHD on development of nonangioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia) | No: Reasonable number of studies, power of individual studies limited | Maybe: If additional evidence available not previously included in the original CER | Maybe: If additional evidence available not included in the original CER. | Maybe: Observational design more practical for longer term outcomes | Maybe: Coding of covariates main issue | Maybe: Model potentially useful for determining clinically meaningful differences
16 | P: The impact of ACEI/ARB in patients with stable IHD on development of angioedema | No: Reasonable number of studies, power of individual studies limited | Maybe: If additional evidence available not previously included in the original CER. | Maybe: if additional evidence available not previously included in the original CER | Maybe: Observational design more practical for longer term outcomes | Maybe: Coding of covariates main issue | Maybe: Model potentially useful for determining clinically meaningful differences

Abbreviations in Table A: ACEI(s)=angiotensin-converting enzyme inhibitor(s), ARB(s)=angiotensin II receptor blocker(s)/antagonist(s), CHF=congestive heart failure, CVA=cerebrovascular accident, IHD=ischemic heart disease, ITT=intention-to-treat, LV=left ventricular, MI=myocardial infarction, PICO=population, interventions, comparators of interest, and outcomes, QOL=quality of life

## Conclusions

In addition to prioritizing future research areas specific to ACEI and ARB therapy in patients with IHD, this pilot study provided several insights into the future research needs assessment process within the broader EPC program. Overall, our experience suggests that the results of stakeholder prioritization exercises performed cold (i.e., without provision of basic information about the status of current research, etc.), are likely to be unstable and may vary greatly depending on what instrument is used. However, provision and discussion of such data appear to lead to greater consensus and more stable ranking of stakeholder preferences. The following specific recommendations are based both on the experience of the investigative team and on explicit feedback received from the stakeholder group.

- The EPC’s review of the recently published literature and ongoing studies was performed and shared with stakeholders between Prioritization Exercises 2 and 3. It was widely agreed by stakeholders that this information was very helpful in their understanding of the evidence gaps and importance of future research. We therefore suggest that this step be performed before engagement of the stakeholder group so that results can be shared with them early in the process. Note that depending on when the future research needs report is developed in the CER process, this information may come directly from the CER and therefore not require an additional step
- Several of the stakeholders felt that they had expertise in related fields (cardiovascular trials, medical decisionmaking, patient advocacy) but were not particularly well-qualified in the specific domain of ACEI and ARB therapy in IHD. Although the breadth of expertise and perspectives in the stakeholder group was intentional, it would have been helpful to the group for the EPC team to provide additional background material and time for the stakeholder group to become familiar with the existing evidence and specific clinical domain. Again, developing the future research needs report as part of the CER process would allow the evidence report to serve as the source of this background material.
- A face-to-face meeting was suggested by both stakeholders and the investigative team. Although such a meeting would have required both time and resources, it would have allowed a more global presentation of the available evidence, the decision analytic model, and, most importantly, an opportunity for the stakeholders to discuss amongst themselves (with the guidance of the EPC team) the reasons for their specific rankings.
- The optimal size of the stakeholder group is unclear. In addition to considerations regarding appropriate representation of all potential stakeholders, the time and resources available for meetings and conference calls, and establishing processes to ensure that all stakeholders have the opportunity to contribute, there are sample size issues raised by using methods such as mean ranking scores—a larger number of rankings might have allowed a greater spread of scores, or sufficient variation in the distribution of scores, to assist in discriminating between different research areas.
- Because the pilot projects were, by necessity, both exploring potential prioritization methods and a specific clinical domain, it is unclear whether specific tools or processes were challenging because of their methodology or because of the specific evidence base (or lack thereof) for the clinical domain. It will therefore be important to look across the entire set of pilot projects for broad themes that can be incorporated into the global EPC program.