# Appendixes

Appendix A Exact Search Strategies

Appendix B Prioritization Tools

Appendix C Summary of Ongoing Studies and Recently Published Studies, Systematic Reviews, and Meta-Analyses

Appendix D Results of Prioritization Exercises