# Summary of Ongoing Studies and Recently Published Studies, Systematic Reviews, and Meta-Analyses

RESEARCH AREA, RECENTLY PUBLISHED AND ONGOING STUDIES
Research Need: Strategies to enhance greater evidence-based use of ACEIs/ARBs
Recently Published Research: None
Active Clinical Trials: Choudhry: Clinical trial of copayment reduction/elimination for post MI therapy (Choudhry, N. A Randomized Evaluation of First-dollar Coverage for Post-MI Secondary Preventive Therapies (Post-MI FREEE). ClinicalTrials.gov.1
Research Need: The impact of ACEI/ARB in patients with stable IHD on incidence of new diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function)
Recently Published Research:; 1. Haywood 2009: Comparison of atrial fibrillation incidence in ALLHAT (lisinopril vs. chlorthalidone vs. amlodipine). No difference in incidence between different classes of medication.2; 2. McMurray 2010: Effect of valsartan vs. placebo in 9306 patients with impaired fasting glucose on the incidence of diabetes and cardiovascular events. 14% risk reduction for incident diabetes; no effect on CV outcomes.3; 3. Pela 2009: Small trial of 26 patients on perindopril vs. placebo on outcome of LV structure and function measured by Doppler tissue echocardiography. Found slightly improved LV systolic/diastolic performance on perindopril.4; 4. Rizos 2010: Olmesartan vs. irbesartan vs. telmisartan effects on glucose metabolism in 151 patients with hypertension and impaired fasting glucose. Found less insulin resistance in telmisartan group compared to other two.5; 5. Schneider 2010: Meta-analysis of 23 trials evaluating ACEI or ARB for prevention of atrial fibrillation. Overall found odds ratio for atrial fibrillation reduced 33%, but significant heterogeneity between trials.6; 6. Verdecchia 2009: Evaluation of ramipril, telmisartan, both, or placebo on development of LVH or regression of LVH in patients with this at baseline (subanalysis from ONTARGET/TRANSCEND). Less incident LVH and greater LVH regression in telmisartan group compared to placebo. No benefit of dual therapy compared to either alone.7
Active Clinical Trials:; 1. Davis: Mechanisms of Ramipril Reduction in the Onset of Type 2 Diabetes. Small mechanistic study looking at glucose metabolism. ClinicalTrials.gov.8; 2. Matsubara: Add-on Effects of Valsartan on Morbi-Mortality (KYOTO HEART Study). Evaluates new diagnosis of atrial fibrillation and DM as secondary outcomes. ClinicalTrials.gov.9; 3. Matsubara: Effects of Telmisartan on Ischemic Cardiovascular Events in High-risk Hypertensive Patients (KCPS). New diagnosis of diabetes is secondary outcome. ClinicalTrials.gov.10; 4. Murohara: Comparison of Valsartan With Amlodipine in Hypertensive Patients With Glucose Intolerance. ClinicalTrials.gov.11; 5. Zanchetti: Prevention of Diabetes and Hypertension (PHIDIAS). Randomize ~6000 patients to different medication and diet interventions (including ACEI and ARB arms) to prevent development of hypertension or diabetes. ClinicalTrials.gov.12
Research Need: Impact of comorbidities (such as hypertension, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single- vs. multi-vessel coronary artery disease) on ACEI/ARB effectiveness or harms in patients with stable IHD
Recently Published Research:; 1. Bohm 2010: Subgroup analysis of ONTARGET/TRANSCEND (ramipril, telmisartan, or both) looking at outcomes in patients with or without ED. Found ED predicted CV events, but no interaction between treatment effect and ED.13; 2. Borghi 2009: Subgroup analysis of Survival of MI Long Term Evaluation study (zofenopril vs. placebo in 1400 patients) comparing RR with ACEI for patients with high baseline and low baseline cholesterol. Possible increased benefit of zofenopril in patients with higher baseline cholesterol.14; 3. McMurray 2010: In patients with impaired glucose tolerance trial of valsartan vs. placebo for new onset DM or cardiovascular outcomes (n = 9300 patients). No difference in CV events.3; 4. Czernichow 2010: Subgroup analysis of PROGRESS (perindopril vs. placebo) examining interaction between treatment effect and BMI. Found comparable risk reduction across entire range of BMIs.15
Active Clinical Trials:; 1. Kingwell: Angiotensin Converting Enzyme (ACE) Inhibition and Peripheral Arterial Disease. Ramipril vs. placebo in ~264 patients with peripheral arterial disease. ClinicalTrials.gov.16
Research Need: The impact of ACEI/ARB in patients with stable IHD on patient quality of life
Recently Published Research: None
Active Clinical Trials: None
Research Need: Impact of demographic differences (such as age, race, sex) on ACEI/ARB effectiveness or harms in patients with stable IHD
Recently Published Research:; 1. Arima 2010: Subgroup analysis of PROGRESS study (perindopril vs. placebo in ~ 6100 patients) comparing effects between Asian and Western participants. Found possible greater RRR in Asian participants compared to Western.17
Active Clinical Trials: None
Research Need: The impact of ACEI/ARB adherence (including differential adherence within and between medication classes) on their effectiveness or harms in patients with stable IHD
Recently Published Research: None
Active Clinical Trials:; 1. Choudhry: Clinical trial of copayment reduction/elimination for post MI therapy (Choudhry, N. A Randomized Evaluation of First-dollar Coverage for Post-MI Secondary Preventive Therapies (Post-MI FREEE). ClinicalTrials.gov.1
Research Need: The benefit of ACEI/ARBs relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms in patients with stable IHD
Recently Published Research:; 1. Persson 2009: Renal effects of aliskiren compared with and in combination with irbesartan in 26 patients with type 2 diabetes, hypertension, and albuminuria. Found similar albuminuria reduction with aliskiren and irbesartan.18; 2. Schwander 2009: Cost-utility analysis of ARB compared to ACEI in primary prevention and nitrendipine (CCB) in secondary prevention in Europe—the HEALTH model. Found eprosartan to be cost-effective compared to ACEI (~25,000Euro/Qualy) and CCB (~9300Euro/Qualy).19
Active Clinical Trials:; 1. Davis: Mechanisms of Ramipril Reduction in the Onset of Type 2 Diabetes. Comparison of ramipril and HCTZ in approximately 48 patients. ClinicalTrials.gov.8; 2. Fogari: Aliskiren Versus Ramipril on Antiproteinuric Effect in Hypertensive, Type 2 Diabetic Patients With Microalbuminuria. Approximately 120 total patients. ClinicalTrials.gov.20; 3. Kashiwagi: Rationale and Design for Shiga Microalbuminuria Reduction Trial. Valsartan vs. amlodipine in approximately 160 patients. ClinicalTrials.gov.21; 4. Kawamori: A Study on Ca Blocker Versus AII Antagonists in Hypertension With Type 2 Diabetes. Approximately 300 patients included. ClinicalTrials.gov.22; 5. Murohara: Comparison of Valsartan With Amlodipine in Hypertensive Patients With Glucose Intolerance. Approximately 1150 enrolled. ClinicalTrials.gov.11
Research Need: The impact of ACEI/ARB in patients with stable IHD on cardiovascular outcomes (such as cardiovascular death, nonfatal MI, CVA, hospitalization for CHF, and surrogates such as blood pressure control, measures of atherosclerosis, etc.)
Recently Published Research:; 1. Arima 2010: Subgroup analysis of PROGRESS study (perindopril vs. placebo) comparing effects between Asian and Western participants. Found 20% RRR for composite of vascular events in Western patients; 38% RRR in Asian participants.17; 2. Bertrand 2010: Subgroup analysis of EUROPA study (perindopril vs. placebo) looking at CV outcomes in patients already on CCB. Addition of perindopril to CCB reduced total mortality by 46% compared to CCB alone.23; 3. Bohm 2010: Subgroup analysis of ONTARGET/TRANSCEND (ramipril, telmisartan, or both) looking at outcomes in patients with or without ED. Found similar results in patients with or without ED.13; 4. Borghi 2009: Subgroup analysis of Survival of MI Long Term Eval study (zofenopril vs. placebo) comparing RR with ACEI for patients with high baseline and low baseline cholesterol. In 6-week outcomes, found zofenopril provided RRR of 43% for death and CHF in high cholesterol patients; 25% RRR in low-cholesterol patients. No difference at 1 year.14; 5. Czernichow 2010: Subgroup analysis of PROGRESS (perindopril vs. placebo) examining interaction between treatment effect and BMI. Perindopril reduced vascular events similarly across BMI range (average RRR ~22%).15; 6. Deftereos 2010: Small trial (86 patients) post-PCI randomized to quinapril or placebo to evaluate impact on in-stent restenosis. Found quinapril reduced in-stent restenosis from 25.6% (placebo) to 9.3% (quinapril).24; 7. Hirohata 2010: Trial (n = 247patients) comparing olmesartan vs. placebo for coronary atherosclerosis progression as measured by intravascular ultrasound. Olmesartan reduced total atheroma volume at 14 months compared to placebo from 5.4% vs. 0.6%.25; 8. McMurray 2010: Trial of valsartan vs. placebo for new onset DM or cardiovascular outcomes (n = 9300 patients). No difference in CV events.3; 9. Pela 2009: Small trial of 26 patients on perindopril vs. placebo on outcome of LV structure and function measured by Doppler tissue echocardiography. Perindopril improved LV systolic/diastolic performance compared to placebo.4; 10. Verdecchia 2009: Secondary outcome from ONTARGET/TRANSCEND (ramipril, telmisartan, or both) on development of LVH. Less incident LVH and greater LVH regression in telmisartan group compared to placebo. No benefit of dual therapy compared to either alone.7
Active Clinical Trials:; 1. Egstrup: Left Ventricular Function After Acute Myocardial Infarction (AMI). Treatment With Angiotensin 2-Receptor Blockade (GLOBAL-Study). ClinicalTrials.gov.26; 2. Matsubara: Add-on Effects of Valsartan on Morbi-Mortality (KYOTO HEART Study). ClinicalTrials.gov.9; 3. Matsubara: Effects of Telmisartan on Ischemic Cardiovascular Events in High-risk Hypertensive Patients (KCPS). ClinicalTrials.gov.10; 4. Murohara: Comparison of Valsartan With Amlodipine in Hypertensive Patients With Glucose Intolerance. ClinicalTrials.gov.11; 5. Ogawa: A Trial of Telmisartan Prevention of Cardiovascular Disease (ATTEMPT-CVD). ClinicalTrials.gov.27; 6. Sakamoto: Candesartan for Prevention of Cardiovascular Events After Cypher or Taxus Coronary Stenting (4C) Trial. ClinicalTrials.gov.28; 7. Zanchetti: Prevention of Diabetes and Hypertension (PHIDIAS). ClinicalTrials.gov.12
Research Need: The impact of ACEI/ARB in patients with stable IHD on utilization and cost of therapy
Recently Published Research:; 1. Boersma 2010: Cost-effectiveness analysis of ARB monotherapy in patients with hypertension (from Netherlands). Modeled cost-effectiveness of 4 ARBs and found olmesartan to be most cost-effective option.29; 2. Schwander 2009: Cost-utility analysis of eprosartan vs. enalapril in primary prevention of CVD in Europe. Found eprosartan to be cost-effective compared to ACEI (~25,000Euro/Qualy) and CCB (~9300Euro/Qualy).19
Active Clinical Trials:; 1. Choudhry: Clinical trial of copayment reduction/elimination for post MI therapy (Choudhry, N. A Randomized Evaluation of First-dollar Coverage for Post-MI Secondary Preventive Therapies (Post-MI FREEE). ClinicalTrials.gov.1
Research Need: The impact of ACEI/ARB in patients with stable IHD on progression of renal insufficiency or development of dialysis dependence
Recently Published Research:; 1. Mann 2009: Analysis of TRANSCEND (telmisartan vs. placebo in 5927 adults) on outcome of dialysis or doubling of serum creatinine. No difference between two groups; however, only 17 patients required dialysis.30; 2. De Cosmo 2009: Cross-sectional study of 1119 patients with DM2 evaluating PPAR-gamma2 Pro12Ala polymorphism and ACE inhibitor therapy on new-onset microalbuminuria. Report significantly higher risk for developing proteinuria in Pro/Pro homozygotes, with this group benefiting more from early ACEI.31; 3. Mehdi 2009: RCT of 81 patients with diabetes, hypertension, and albuminuria on ACEI. Patients randomized to losartan add-on or spironolactone for 48 weeks. Found that addition of spironlactone to ACEI was better than adding ARB to ACEI for proteinuria reduction.32; 4. Persson 2009: RCT of 26 patients with diabetic nephropathy comparing aliskirin, irbesartan or both. Aliskirin and irbesartan produced similar reductions in proteinuria. The combination of the two agents reduced proteinuria more than monotherapy.18
Active Clinical Trials:; 1. Antonopoulos: Triple Blockade of the Renin Angiotensin Aldosterone System in Diabetic (Type 1&2) Proteinuric Patients. ClinicalTrials.gov.33; 2. Camargo: Aspirin and Enalapril in Microalbuminuric Type 2 Diabetes Mellitus Patients. ClinicalTrials.gov.34; 3. Chen: Effectiveness Study on Fosinopril and/or Losartan in Patients With Chronic Kidney Disease Stage 3 (FLIP). ClinicalTrials.gov.35; 4. Fried: NEPHRON-D: Diabetes iN Nephropathy Study. ClinicalTrials.gov.36; 5. Hou: Safety of Dual Blockage of Rennin-angiotensin System in Patients With Advanced Renal Insufficiency (SDBRAS). ClinicalTrials.gov.37; 6. Kashiwagi: Rationale and Design for Shiga Microalbuminuria Reduction Trial. ClinicalTrials.gov.21; 7. Murohara: Comparison of Valsartan With Amlodipine in Hypertensive Patients With Glucose Intolerance. Includes evaluation of renal outcomes as secondary endpoint. ClinicalTrials.gov.11; 8. Ogawa: A Trial of Telmisartan Prevention of Cardiovascular Disease (ATTEMPT-CVD). ClinicalTrials.gov.27; 9. Remuzzi: Preventing ESRD in Overt Nephropathy of Type 2 Diabetes (VALID). ClinicalTrials.gov.38; 10. Ruggenenti: Preventing Microalbuminuria in Type 2 Diabetes (VARIETY). ClinicalTrials.gov.39; 11. Zatz: Effect of Enalapril and Losartan Association Therapy on Proteinuria and Inflammatory Biomarkers in Diabetic Nephropathy: a Clinical Trial on Type 2 Diabetes Mellitus. ClinicalTrials.gov.40
Research Need: Impact of concurrent medications (such as antiplatelet agents, lipid-lowering medications, other antihypertensives) on ACEI/ARB effectiveness or harms in patients with stable IHD
Recently Published Research: Bertrand 2010: Subgroup analysis of EUROPA study (perindopril vs. placebo) looking at CV outcomes in patients already on CCB. Addition of perindopril to CCB reduced total mortality by 46% compared to CCB alone.23
Active Clinical Trials:; 1. Camargo: Aspirin and Enalapril in Microalbuminuric Type 2 Diabetes Mellitus Patients. ClinicalTrials.gov.34; 2. Gupta: Effects of ROSIglitazone on Inflammatory Markers and Adipokines in Diabetic Patients Using an Angiotensin Receptor Blocker (TELmisartan) - The ROSITEL Study. ClinicalTrials.gov.41
Research Need: Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on AC-I/ARB effectiveness or harms in patients with stable IHD
Recently Published Research:; 1. De Cosmo 2009: Cross-sectional study of 1119 patients with type 2 DM evaluating PPAR-gamma2 Pro12Ala polymorphism and ACE inhibitor therapy on new-onset microalbuminuria. Report significantly higher risk for developing proteinuria in Pro/Pro homozygotes, with this group benefiting more from early ACEI.31; 2. Donner 2009: Sub analysis of RCT (n = 217 patients) of losartan vs. three other antihypertensive medications. Evaluates CYP2C9 genotype and activity of rennin-angiotensin system. No impact on efficacy of losartan.42; 3. Nordestgaard 2010: Subanalysis of LIFE RCT (losartan vs. atenolol) in 3503 high-risk patients. Evaluated effect of ACE gene insertion/deletion and 12 other polymorphisms on clinical outcomes and response to treatment in the LIFE study. (None influenced treatment response.)43
Active Clinical Trials:; 1. Bhansali: Association of Angiotensin II Type 1 R Gene Polymorphism and Diabetic Nephropathy in Type 2 Diabetes. ClinicalTrials.gov.44
Research Need: Impact of class effect (impact of differences between specific agents within each class) of ACEI and ARBs on their effectiveness or harms in patients with stable IHD
Recently Published Research:; 1. de Luis 2010: Telmisartan vs. olmesartan on metabolic parameters in 65 overweight and obese patients with hypertension. Found that telmisartan may have greater impact than olmesartan on insulin resistance.45; 2. Fogari 2009: Telmisartan vs. eprosartan on insulin sensitivity in 50 overweight hypertensive patients. Found that telmisartan may have greater impact than eprosartan on insulin resistance.46; 3. Hamada 2010: Telmisartan vs. losartan vs. candesartan on uric acid levels in 42 hypertensive patients. Found uric acid levels declined in telmisartan, candesartan, but not losartan arms.47; 4. Rizos 2010: Olmesartan vs. irbesartan vs. telmisartan effects on glucose metabolism in 151 patients with hypertension and impaired fasting glucose. Found telmisartan had most favorable effects on insulin resistance.5
Active Clinical Trials:; 1. Lim: Comparison of Effects of Telmisartan and Valsartan on Neointima Volume in Diabetes. ClinicalTrials.gov.48
Research Need: Impact of the dose response (impact of medication dose or dosing interval) of ACEIs and ARBs on their effectiveness or harms in patients with stable IHD
Recently Published Research: None
Active Clinical Trials: None
Research Need: The impact of ACEI/ARB in patients with stable IHD on development of nonangioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia)
Recently Published Research:; 1. Chrysant 2010: Short 12-week RCT evaluating safety and tolerability of an olmesartan medoxomil-based regimen in 130 patients with stage 1 hypertension. Found no difference between olmesartan and placebo in safety and tolerability.49
Active Clinical Trials:; 1. Golik: ACEIs and ARBs Treatment in Diabetic Patients-Drug Interactions and Adverse Drug Effects. ClinicalTrials.gov.50; 2. Hou: Safety of Dual Blockage of Rennin-angiotensin System in Patients With Advanced Renal Insufficiency (SDBRAS). ClinicalTrials.gov.37; 3. Zanchetti: Prevention of Diabetes and Hypertension (PHIDIAS). Randomize ~6000 patients to different medication and diet interventions (including ACEI and ARB arms); evaluate safety/tolerability as secondary outcomes. ClinicalTrials.gov.12
Research Need: The impact of ACEI/ARB in patients with stable IHD on development of angioedema
Recently Published Research:; 1. Brown 2009: One case-control study proposing RR of 4.5 for ACEI angioedema for patients on concurrent vildagliptin.51
Active Clinical Trials: None

Abbreviations: ACEI(s) = angiotensin-converting enzyme inhibitor(s), ARB(s) = angiotensin II receptor blocker(s)/antagonist(s), BMI = body mass index, CCB = calcium channel blocker, CHF = congestive heart failure, CV = cardiovascular, CVA = cerebrovascular accident, CVD = cardiovascular disease, DM = diabetes mellitus, ED = erectile dysfunction, HCTZ = hydrochlorothiazide, IHD = ischemic heart disease, LV = left ventricular, LVH = left ventricular hypertrophy, MI = myocardial infarction, PCI = percutaneous coronary intervention, RCT = randomized controlled trial, RR = relative risk, RRR = relative risk reduction

## References

1 Choudhry N. A Randomized Evaluation of First-dollar Coverage for Post-MI Secondary Preventive Therapies (Post-MI FREEE). ClinicalTrials.gov (ID:NCT00566774).
2 Haywood LJ, Ford CE, Crow RS, et al. Atrial fibrillation at baseline and during follow-up in ALLHAT (Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial). J Am Coll Cardiol. 2009;54(22):2023-2031. [pmid: 19926008].
3 McMurray JJ, Holman RR, Haffner SM, et al. Effect of valsartan on the incidence of diabetes and cardiovascular events. N Engl J Med. 2010;362(16):1477-1490. [pmid: 20228403].
4 Pela G, Pattoneri P, Passera M, et al. Long-term effects of perindopril on left ventricular structure and function in patients with stable coronary artery disease: a conventional and Doppler tissue echocardiographic pilot study. J Cardiovasc Med (Hagerstown). 2009;10(10):781-786. [pmid: 19525856].
5 Rizos CV, Milionis HJ, Kostapanos MS, et al. Effects of rosuvastatin combined with olmesartan, irbesartan, or telmisartan on indices of glucose metabolism in Greek adults with impaired fasting glucose, hypertension, and mixed hyperlipidemia: a 24-week, randomized, open-label, prospective study. Clin Ther. 2010;32(3):492-505. [pmid: 20399986].
6 Schneider MP, Hua TA, Bohm M, et al. Prevention of atrial fibrillation by Renin-Angiotensin system inhibition a meta-analysis. J Am Coll Cardiol. 2010;55(21):2299-2307. [pmid: 20488299].
7 Verdecchia P, Sleight P, Mancia G, et al. Effects of telmisartan, ramipril, and their combination on left ventricular hypertrophy in individuals at high vascular risk in the Ongoing Telmisartan Alone and in Combination With Ramipril Global End Point Trial and the Telmisartan Randomized Assessment Study in ACE Intolerant Subjects With Cardiovascular Disease. Circulation. 2009;120(14):1380-1389. [pmid: 19770395].
8 Davis S. Mechanisms of Ramipril Reduction in the Onset of Type 2 Diabetes. ClinicalTrials.gov (ID:NCT00574834).
9 Matsubara H. Add-on Effects of Valsartan on Morbi-Mortality (KYOTO HEART Study). ClinicalTrials.gov (ID:NCT00149227).
10 Matsubara H. Effects of Telmisartan on Ischemic Cardiovascular Events in High-risk Hypertensive Patients (KCPS). ClinicalTrials.gov (ID:NCT00863980).
11 Murohara T. Comparison of Valsartan With Amlodipine in Hypertensive Patients With Glucose Intolerance. ClinicalTrials.gov (ID:NCT00129233).
12 Zanchetti A. Prevention of Diabetes and Hypertension (PHIDIAS). ClinicalTrials.gov (ID:NCT00456963).
13 Bohm M, Baumhakel M, Teo K, et al. Erectile dysfunction predicts cardiovascular events in high-risk patients receiving telmisartan, ramipril, or both: The ONgoing Telmisartan Alone and in combination with Ramipril Global Endpoint Trial/Telmisartan Randomized AssessmeNt Study in ACE iNtolerant subjects with cardiovascular Disease (ONTARGET/TRANSCEND) Trials. Circulation. 2010;121(12):1439-1446. [pmid: 20231536].
14 Borghi C, Cicero AF, Bacchelli S, et al. Serum cholesterol levels on admission and survival in patients with acute myocardial infarction treated with zofenopril: a post hoc analysis of the Survival of Myocardial Infarction Long-term Evaluation trial. Fundam Clin Pharmacol. 2009;23(5):641-648. [pmid: 19656211].
15 Czernichow S, Ninomiya T, Huxley R, et al. Impact of blood pressure lowering on cardiovascular outcomes in normal weight, overweight, and obese individuals: the Perindopril Protection Against Recurrent Stroke Study trial. Hypertension. 2010;55(5):1193-1198. [pmid: 20212271].
16 Kingwell BA. Angiotensin Converting Enzyme (ACE) Inhibition and Peripheral Arterial Disease. ClinicalTrials.gov (ID:NCT00681226).
17 Arima H, Anderson C, Omae T, et al. Perindopril-based blood pressure lowering reduces major vascular events in Asian and Western participants with cerebrovascular disease: the PROGRESS trial. J Hypertens. 2010;28(2):395-400. [pmid: 19864958].
18 Persson F, Rossing P, Reinhard H, et al. Renal effects of aliskiren compared with and in combination with irbesartan in patients with type 2 diabetes, hypertension, and albuminuria. Diabetes Care. 2009;32(10):1873-1879. [pmid: 19587362].
19 Schwander B, Gradl B, Zollner Y, et al. Cost-utility analysis of eprosartan compared to enalapril in primary prevention and nitrendipine in secondary prevention in Europe—the HEALTH model. Value Health. 2009;12(6):857-871. [pmid: 19508663].
20 Fogari R. Aliskiren Versus Ramipril on Antiproteinuric Effect in Hypertensive, Type 2 Diabetic Patients With Microalbuminuria. ClinicalTrials.gov (ID:NCT01038895).
21 Kashiwagi A. Rationale and Design for Shiga Microalbuminuria Reduction Trial. ClinicalTrials.gov (ID:NCT00202618).
22 Kawamori R. A Study on Ca Blocker Versus AII Antagonists in Hypertension With Type 2 Diabetes. ClinicalTrials.gov (ID:NCT00144144).
23 Bertrand ME, Ferrari R, Remme WJ, et al. Clinical synergy of perindopril and calcium-channel blocker in the prevention of cardiac events and mortality in patients with coronary artery disease. Post hoc analysis of the EUROPA study. Am Heart J. 2010;159(5):795-802. [pmid: 20435188].
24 Deftereos S, Giannopoulos G, Kossyvakis C, et al. Effect of quinapril on in-stent restenosis and relation to plasma apoptosis signaling molecules. Am J Cardiol. 2010;105(1):54-58. [pmid: 20102890].
25 Hirohata A, Yamamoto K, Miyoshi T, et al. Impact of olmesartan on progression of coronary atherosclerosis a serial volumetric intravascular ultrasound analysis from the OLIVUS (impact of OLmesarten on progression of coronary atherosclerosis: evaluation by intravascular ultrasound) trial. J Am Coll Cardiol. 2010;55(10):976-982. [pmid: 20202514].
26 Egstrup K. Left Ventricular Function After Acute Myocardial Infarction (AMI). Treatment With Angiotensin 2-Receptor Blockade (GLOBAL-Study). ClinicalTrials.gov (ID:NCT00125645).
27 Ogawa H. A Trial of Telmisartan Prevention of Cardiovascular Disease (ATTEMPT-CVD). ClinicalTrials.gov (ID:NCT01075698).
28 Sakamoto T. Candesartan for Prevention of Cardiovascular Events After Cypher or Taxus Coronary Stenting (4C) Trial. ClinicalTrials.gov (ID:NCT00139386).
29 Boersma C, Voors AA, Visser ST, et al. Cost effectiveness of angiotensin receptor blocker monotherapy in patients with hypertension in the Netherlands: a comparative analysis using clinical trial and drug utilization data. Am J Cardiovasc Drugs. 2010;10(1):49-54. [pmid: 20104934].
30 Mann JF, Schmieder RE, Dyal L, et al. Effect of telmisartan on renal outcomes: a randomized trial. Ann Intern Med. 2009;151(1):1-10. [pmid: 19451556].
31 De Cosmo S, Motterlini N, Prudente S, et al. Impact of the PPAR-gamma2 Pro12Ala polymorphism and ACE inhibitor therapy on new-onset microalbuminuria in type 2 diabetes: evidence from BENEDICT. Diabetes. 2009;58(12):2920-2929. [pmid: 19720797].
32 Mehdi UF, Adams-Huet B, Raskin P, et al. Addition of angiotensin receptor blockade or mineralocorticoid antagonism to maximal angiotensin-converting enzyme inhibition in diabetic nephropathy. J Am Soc Nephrol. 2009;20(12):2641-2650. [pmid: 19926893].
33 Antonopoulos P. Triple Blockade of the Renin Angiotensin Aldosterone System in Diabetic (Type 1&2) Proteinuric Patients. ClinicalTrials.gov (ID:NCT00961207).
34 Camargo E. Aspirin and Enalapril in Microalbuminuric Type 2 Diabetes Mellitus Patients. ClinicalTrials.gov (ID:NCT00427271).
35 Chen N. Effectiveness Study on Fosinopril and/or Losartan in Patients With Chronic Kidney Disease Stage 3 (FLIP). ClinicalTrials.gov (ID:NCT00565396).
36 Fried L. VA NEPHRON-D: Diabetes iN Nephropathy Study. ClinicalTrials.gov (ID:NCT00555217).
37 Hou F. Safety of Dual Blockage of Rennin-angiotensin System in Patients With Advanced Renal Insufficiency (SDBRAS). ClinicalTrials.gov (ID:NCT00630708).
38 Remuzzi G. Preventing ESRD in Overt Nephropathy of Type 2 Diabetes (VALID). ClinicalTrials.gov (ID:NCT00494715).
39 Ruggenenti P. Preventing Microalbuminuria in Type 2 Diabetes (VARIETY). ClinicalTrials.gov (ID:NCT00503152).
40 Zatz R. Effect of Enalapril and Losartan Association Therapy on Proteinuria and Inflammatory Biomarkers in Diabetic Nephropathy: a Clinical Trial on Type 2 Diabetes Mellitus. ClinicalTrials.gov (ID:NCT00419835).
41 Gupta M. Effects of ROSIglitazone on Inflammatory Markers and Adipokines in Diabetic Patients Using an Angiotensin Receptor Blocker (TELmisartan)—The ROSITEL Study. ClinicalTrials.gov (ID:NCT00486187).
42 Donner KM, Hiltunen TP, Suonsyrja T, et al. CYP2C9 genotype modifies activity of the renin-angiotensin-aldosterone system in hypertensive men. J Hypertens. 2009;27(10):2001-2009. [pmid: 19593208].
43 Nordestgaard BG, Kontula K, Benn M, et al. Effect of ACE insertion/deletion and 12 other polymorphisms on clinical outcomes and response to treatment in the LIFE study. Pharmacogenet Genomics. 2010;20(2):77-85. [pmid: 20065889].
44 Bhansali A. Association of Angiotensin II Type 1 R Gene Polymorphism and Diabetic Nephropathy in Type 2 Diabetes. ClinicalTrials.gov (ID:NCT01069549).
45 de Luis DA, Conde R, Gonzalez-Sagrado M, et al. Effects of telmisartan vs. olmesartan on metabolic parameters, insulin resistance and adipocytokines in hypertensive obese patients. Nutr Hosp. 2010;25(2):275-279. [pmid: 20449538].
46 Fogari R, Zoppi A, Ferrari I, et al. Comparative effects of telmisartan and eprosartan on insulin sensitivity in the treatment of overweight hypertensive patients. Horm Metab Res. 2009;41(12):893-898. [pmid: 19708000].
47 Hamada T, Mizuta E, Kondo T, et al. Effects of a low-dose antihypertensive diuretic in combination with losartan, telmisartan, or candesartan on serum urate levels in hypertensive patients. Arzneimittelforschung. 2010;60(2):71-75. [pmid: 20329654].
48 Lim D. Comparison of Effects of Telmisartan and Valsartan on Neointima Volume in Diabetes. ClinicalTrials.gov (ID:NCT00599885).
49 Chrysant SG. Safety and tolerability of an olmesartan medoxomil-based regimen in patients with stage 1 hypertension: a randomized, double-blind, placebo-controlled study. Clin Drug Investig. 2010;30(7):473-482.
50 Golik A. ACEIs and ARBs Treatment in Diabetic Patients -Drug Interactions and Adverse Drug Effects. ClinicalTrials.gov (ID:NCT00437775).
51 Brown NJ, Byiers S, Carr D, et al. Dipeptidyl peptidase-IV inhibitor use associated with increased risk of ACE inhibitor-associated angioedema. Hypertension. 2009;54(3):516-523. [pmid: 19581505].