# Prioritization Tools

The material presented below represents the tools used in each of three prioritization exercises conducted with the stakeholder group.

## Prioritization Exercise 1

The following survey was administered to stakeholders electronically on July 19, 2010, using SurveyMonkey™ software. In this survey, stakeholders were asked to use a 5-point Likert scale to rate the importance of further research in the areas of the 16 identified research gaps. Possible responses ranged from “Not at all important” to “Very important.” A free text field was offered to allow stakeholders to enter additional research areas for consideration. Stakeholders were also asked to rank their top five research priorities from the complete list of options, including any additional considerations entered into the free text field.

## Prioritization Exercise 2

The following qualitative prioritization exercise was conducted with stakeholders on July 28, 2010. In this exercise, stakeholders were provided with a PDF document including the results of Prioritization Exercise 1 and a list of priority setting criteria that could be used when considering the appropriate priority for the research questions. Summary tables describing the evidence base regarding the comparative effectiveness of ACE inhibitor and ARB therapy in patients with IHD1–2 or hypertension3–4 were also distributed to the group. Stakeholders were asked to prioritize each research area in order from 1 to 16.

### References

1 Coleman CI, Baker WL, Kluger J, et al. Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease. (Prepared by the University of Connecticut/Hartford Hospital Evidence-based Practice Center under Contract No. 290-2007-10067-I). Rockville, MD. Agency for Healthcare Research and Quality. October. 2009. Available at: http://www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed September 7, 2010.
2 Baker WL, Coleman CI, Kluger J, et al. Systematic review: comparative effectiveness of angiotensin-converting enzyme inhibitors or angiotensin II-receptor blockers for ischemic heart disease. Ann Intern Med. 2009;151(12):861-871. [pmid: 20008762].
3 Matchar DB, McCrory DC, Orlando LA, et al. Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension Comparative Effectiveness Review No 10 (Prepared by Duke Evidence-based Practice Center under Contract No 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. November. 2007. Available at: http://www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed September 10, 2010.
4 Matchar DB, McCrory DC, Orlando LA, et al. Systematic review: comparative effectiveness of angiotensin-converting enzyme inhibitors and angiotensin II receptor blockers for treating essential hypertension. Ann Intern Med. 2008;148(1):16-29. [pmid: 17984484].

## Prioritization Exercise 3

The following PowerPoint slideshow was presented during a conference call held with stakeholders on September 3, 2010. During this call, the group discussed the results of Prioritization Exercise 2, findings from the Duke EPC’s search of recently published literature and ongoing trials, findings from the decision analytic model analysis, and potential changes to the existing ranking based on the body of newly available information.

Slide 1

Slide 2

Slide 3

Slide 4

Slide 5

Slide 6

Slide 7

Slide 8

Slide 9

Slide 10

Slide 11

Slide 12

Slide 13

Slide 14

Slide 15

Slide 16

Slide 17

The following prioritization exercise was conducted with stakeholders on September 7, 2010. In this final survey, stakeholders were provided with a Word document including 1) the qualitative rankings as established in Prioritization Exercise 2 and 2) summaries of the recently published literature and ongoing trials that might inform each research area. Stakeholders were asked to consider these findings and then complete a final ranking of the research areas, again assigning priorities from 1 to 16.

Prioritized Future Research Needs for Comparative Effectiveness of ACEI vs. ARBs for Ischemic Heart Disease:

Summary of Recently Published Research and Active Clinical Trials

* Reference: Institute of Medicine. Initial national priorities for comparative effectiveness research. Washington, DC: Institute of Medicine, 2009.