# Exact Search Strategies

We ran three separate searches of electronic databases to identify ongoing and recently published studies potentially relevant to the evidence gaps identified in this report:

1. A search of ClinicalTrials.gov for ongoing studies.
2. An update of the PubMed^®^ search used in the Comparative Effectiveness Review (CER) on “Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease.”1
3. A search of PubMed for systematic reviews and meta-analyses.

Exact search strings used in the three searches are given below.

## Search of ClinicalTrials.gov (last search date September 2, 2010)

(Ischemic Heart Disease OR coronary Artery Disease OR Diabetes OR Chronic Kidney Disease OR Peripheral Artery Disease) [DISEASE] AND (ACEI OR ACE-I OR ARB OR Angiotensin) [TREATMENT] AND (“Adult” OR “Senior”) [AGE-GROUP]

## Update of PubMed Search Used in CER on “Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease” (last search date August 23, 2010)

((coronary artery disease[mesh] OR coronary disease[mesh] OR myocardial ischemia[mesh] OR angina pectoris[mesh] OR angina, unstable[mesh] OR arterial occlusive diseases[mesh] OR peripheral vascular diseases[mesh] OR vascular diseases[mesh] OR atherosclerosis[mesh] OR cardiovascular diseases[mesh] OR carotid artery diseases[mesh]) OR (“preserved left” OR “stable CAD” OR “stable chd” OR “stable coronary” OR “preserved coronary” OR “preserved systolic” OR “preserved ventricular” OR “preserved lvef” OR “preserved ef” OR “preserved ejection” OR “intact left” OR “intact systolic” OR “intact ventricular” OR “intact lvef” OR “intact ef” OR “normal systolic” OR “intact ventricular” OR “intact lvef” OR “intact ef” OR “normal systolic” OR “normal ventricular” OR “normal lvef” OR “normal ef”)) AND ((randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR placebo[tiab] OR clinical trials as topic[mesh] OR randomly[tiab] OR trial[ti]) AND humans[mesh]) AND (alacepril OR benazepril OR captopril OR ceronapril OR cilazapril OR delapril OR enalapril OR fosinopril OR imidapril OR libenzapril OR lisinopril OR moexipril OR moveltipril OR pentopril OR perindopril OR quinapril OR ramipril OR spirapril OR temocapril OR teprotide OR trandolapril OR zofenopril OR losartan OR olmesartan OR telmisartan OR valsartan OR eprosartan OR candesartan OR tasosartan OR irbesartan OR angiotensin-converting enzyme inhibitors[mesh] OR angiotensin II type 1 receptor blockers[mesh] OR ACEI OR ARB) AND ((“2009/07/01”[PDat] : “3000”[PDat])) AND English[lang]

## Search of PubMed for systematic reviews and meta-analyses (last search date August 31, 2010)

(((coronary artery disease[mesh] OR coronary disease[mesh] OR myocardial ischemia[mesh] OR angina pectoris[mesh] OR angina, unstable[mesh] OR arterial occlusive diseases[mesh] OR peripheral vascular diseases[mesh] OR vascular diseases[mesh] OR atherosclerosis[mesh] OR cardiovascular diseases[mesh] OR carotid artery diseases[mesh]) OR (“preserved left” OR “stable CAD” OR “stable chd” OR “stable coronary” OR “preserved coronary” OR “preserved systolic” OR “preserved ventricular” OR “preserved lvef” OR “preserved ef” OR “preserved ejection” OR “intact left” OR “intact systolic” OR “intact ventricular” OR “intact lvef” OR “intact ef” OR “normal systolic” OR “intact ventricular” OR “intact lvef” OR “intact ef” OR “normal systolic” OR “normal ventricular” OR “normal lvef” OR “normal ef”)) AND (alacepril OR benazepril OR captopril OR ceronapril OR cilazapril OR delapril OR enalapril OR fosinopril OR imidapril OR libenzapril OR lisinopril OR moexipril OR moveltipril OR pentopril OR perindopril OR quinapril OR ramipril OR spirapril OR temocapril OR teprotide OR trandolapril OR zofenopril OR losartan OR olmesartan OR telmisartan OR valsartan OR eprosartan OR candesartan OR tasosartan OR irbesartan OR angiotensin-converting enzyme inhibitors[mesh] OR angiotensin II type 1 receptor blockers[mesh] OR ACEI OR ARB) AND ((“2009/07/01”[PDat] : “3000”[PDat])) AND English[lang]) AND (review[pt] OR “meta-analysis”[pt] OR meta-analysis OR meta-analy* OR metaanaly* OR metanaly* OR review OR (overview AND systematic) OR (review AND systematic))

## Reference

1 Coleman CI, Baker WL, Kluger J, et al. Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease. (Prepared by the University of Connecticut/Hartford Hospital Evidence-based Practice Center under Contract No. 290-2007-10067-I). Rockville, MD. Agency for Healthcare Research and Quality. October. 2009. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed September 7, 2010.