# Abbreviations

ACE: Angiotensin-converting enzyme
ACEI(s): Angiotensin-converting enzyme inhibitor(s) [used in tables only]
AHRQ: Agency for Healthcare Research and Quality
ARB(s): Angiotensin II receptor blocker(s)/antagonist(s)
CER: Comparative Effectiveness Review
CHF: Congestive heart failure
CPT: Current Procedural Terminology
CVA: Cerebrovascular accident
EPC: Evidence-based Practice Centers
ICD-9: International Classification of Diseases, Ninth Revision
IHD: Ischemic heart disease
ITT: Intention-to-treat
LV: Left ventricular
LVEF: Left ventricular ejection fraction
MI: Myocardial infarction
PICO: Population, interventions, comparators of interest, and outcomes
PICOTS: Population, interventions, comparators of interest, outcomes, timing, and settings
QOL: Quality of life
RCT: Randomized controlled trial