# Methods

The key steps we completed are outlined in Figure 1 and described below:

Figure 1 Steps in project

Figure 1 is a flow chart that lists the various steps in the project. The steps include: 1) identification and abstraction of research gaps from evidence report (2008) and five published manuscripts; 2) feedback from authors of 2008 evidence report; 3) translation of research gaps into researchable questions; 4) online and in-person feedback on research questions from local stakeholders; 5) online feedback, consensus development, and prioritization of research questions by external stakeholders (Delphi approach); 6) prioritization of outcomes for key questions I and II ; 7) refinement of final research questions and development of conceptual models to display research gaps; and 8) evaluation of entire process by evidence report authors, local stakeholders, and external stakeholders.

## Step 1 Identification and Abstraction of Research Gaps from Evidence Report (2008) and Five Published Manuscripts

We used the 2008 evidence report to identify gaps in the evidence for the management of GDM.7 Two authors independently abstracted gaps from the report using custom-designed data abstraction forms in Excel spreadsheets (Microsoft,™ Redmond, WA). Research gaps were abstracted from the “Discussion” section of the report, which includes the “Summary of Key Findings,” “Conclusions,” “Future Research,” and “Implications” sections. Where necessary, authors referred back to the “Results” section of the report. The lists of research gaps abstracted by the two authors were compared and a combined list was created based on consensus. In addition, one author abstracted additional research gaps from the five published manuscripts that were derived from the report.8–12 Information about gaps identified in the manuscripts was used to add to or clarify the items in the list of gaps abstracted from the report.

We developed a conceptual model to identify and illustrate the overall location of each of the original report’s key questions and the main types of outcomes.

## Step 2 Feedback from Authors of 2008 Evidence Report

Three of the eleven authors of the 2008 evidence report on GDM are members of the research team for this project. We contacted the eight other authors to request their individual review and feedback on the list of gaps. For each key question we organized research gaps by population, intervention and comparisons, outcomes, settings, and study designs. We asked the authors to provide their feedback as well as any specific clarifications or additional gaps using Word documents (Microsoft, ™ Redmond, WA). We contacted these eight authors via email.

## Step 3 Translation of Research Gaps into Researchable Questions

After receiving feedback, clarifications, and additional gaps from the authors of the 2008 evidence report we revised the list of gaps as appropriate. These gaps were then translated into a list of researchable questions. These research questions were developed using the PICO (population, intervention, comparison, and outcomes) framework. The use of this structured framework facilitated the further development and refinement of the specific elements needed for a well-defined research question. The list of research questions was reviewed by all members of the research team to ensure accuracy and completeness.

It is worth clarifying that we refer to the questions from the original report as “key questions” and newly generated researchable questions in this project as “research questions.”

## Step 4 Online and In-Person Feedback on Research Questions from Local Stakeholders

We invited a local group of stakeholders from our own institution to provide feedback on the research questions we developed (see Table 2). This group comprised six members representing four perspectives with broad clinical, research, and patient advocacy expertise (two physicians [obstetricians and gynecologists], one nutritionist/dietitian, one epidemiologist/methodologist, and two members that served as proxy for the patient/consumer perspective). These stakeholders were contacted via email. We obtained a Disclosure Statement from each stakeholder to ensure that potential conflicts of interest were disclosed. The list of local stakeholders and their Disclosure Statements were approved by AHRQ.

Table 2 Composition of groups of local and external stakeholders

Areas of Expertise | Number of Local Stakeholders (from Johns Hopkins) | Number of External Stakeholders (not from Johns Hopkins)
Physicians (Obstetricians and Gynecologists) | 2 | 2
Nutritionists/Dietitians | 1 | 2
Epidemiologists/Methodologists | 1 | 2
Research Funders | - | 2
Patient/Consumer Representatives | 2 | 2
Total | 6 | 9^*^

* One external stakeholder served as both a nutritionist/dietitian and an epidemiologist/methodologist. Therefore, there were 9 external stakeholders.

### Online Feedback

Each local stakeholder was asked to provide feedback on each research question using an online tool (SurveyGizmo,™ Widgix LLC, Boulder, CO). For each research question, we asked the stakeholders to comment on:

- whether or not the research question was worded clearly, and if not, to suggest changes;
- the likely clinical benefit/importance of addressing the research question (on a 9-point Likert scale with higher score indicating greater clinical benefit/importance); and
- the likely ability for researchers to conduct a study to address the research question (on a 9-point Likert scale with higher score indicating higher feasibility).

These scores helped the team to refine the questions and were provided to help direct the subsequent discussion and refinement of the questions during the in-person meeting. The scores helped to illuminate any differences in the rating of clinical importance and were used to help clarify the wording and scope of the questions. Questions were not removed at this stage. In addition, we asked stakeholders to provide overall suggestions or clarifications. We then refined the research questions as appropriate.

### In-Person Meeting To Provide Additional Feedback

The same group of local stakeholders was invited to participate in an in-person meeting which lasted 1.5 hours. The purpose of this meeting was to present a summary of the comments and results from the online feedback process, to present the refined list of research questions (organized by key question), and to solicit further feedback on these research questions. In addition to reviewing the research questions from the online feedback, we asked stakeholders to consider study design needs and challenges for each of the research questions to gain an interactive exploration of these issues.

## Step 5 Online Feedback, Consensus Development, and Prioritization of Research Questions by External Stakeholders (Delphi Approach)

We invited an external group of stakeholders from various other institutions across the United States (see Table 2). This group comprised representatives of five perspectives (two physicians [obstetricians and gynecologists], two nutritionists/dietitians, two epidemiologists/methodologists, two research funders, and two members that served as proxy for the patient/consumer perspective). These stakeholders were contacted via email. One of the external stakeholders was deemed to have expertise in two areas (nutrition/dietetics and epidemiology/methodology) and thus represented both. As a consequence, there were nine stakeholders. We believe that inviting stakeholders from a range of relevant disciplines ensured a balanced and broad perspective on research needs for GDM. We obtained a Disclosure Statement from each external stakeholder to ensure that potential conflicts of interest were disclosed. The list of external stakeholders and their Disclosure Statements were approved by AHRQ.

### Delphi Approach

We used the Delphi method for consensus development.13 An online tool (SurveyGizmo,™ Widgix LLC, Boulder, CO) was used to carry out the process. We decided a priori that this iterative process would be repeated until consensus is reached, with the number of rounds not to exceed three. In the opening Delphi round, stakeholders were provided the list of research questions and for each research question were asked to comment on:

- whether or not the research question was worded clearly, and if not, to suggest changes; and
- the likely clinical benefit/importance of addressing the research question (on a 9-point Likert scale with higher score indicating greater clinical benefit/importance).

We then refined the research questions as appropriate. We used the external stakeholders’ ratings of clinical benefit/importance to classify each research question as follows:

- high clinical benefit/importance (between 7 and 9),
- medium clinical benefit/importance (between 4 and 6), and
- low clinical benefit/importance (between 1 and 3).

We defined consensus to have been achieved if at least 75 percent (7 out of 9) of external stakeholders rated clinical benefit/importance within a single category (high, medium, or low). Research questions for which consensus had been achieved were not retained in the list of research questions for the next Delphi round(s). The wording and clinical benefit/importance of these questions were deemed to have been agreed upon.

In the next two Delphi rounds, we provided stakeholders with the refined research questions for which consensus was not achieved. For each question, stakeholders were provided with a summary (mean, range) of the ratings of clinical benefit/importance those questions received in the previous Delphi round. In addition, we provided a brief synopsis of comments (with identifying information removed).

## Step 6 Prioritization of Outcomes for Key Questions I and II

Because key questions I and II each had a long list of short- and long-term maternal and neonatal outcomes, we asked external stakeholders to rank the top three outcomes (in research questions related to those key questions) that would be essential to include in a clinical trial to address these research questions.

## Step 7 Refinement of Final Research Questions and Development of Conceptual Models To Display Research Gaps

For each key question, we developed a conceptual model to identify and illustrate the location of research questions of high clinical benefit/importance and their relevant outcomes.

## Step 8 Evaluation of Entire Process by Evidence Report Authors, Local Stakeholders, and External Stakeholders

We asked all those who participated in the project (other authors of the 2008 evidence report on GDM, local stakeholders, and external stakeholders) to evaluate our process. We used an online tool (SurveyGizmo,™ Widgix LLC, Boulder, CO) to obtain their feedback. Respondents were provided a summary of the process (Methods section of this report) and preliminary results (including tables, figures, and appendixes). They were asked to comment on:

- whether or not they felt they had had adequate information to participate effectively;
- which mode of participation they would have preferred (i.e., web-based form, phone, in-person);
- whether or not, after looking at the final list of research questions, they felt that we accomplished our objective;
- whether or not the local stakeholder group was comprehensive (i.e., whether it was adequate to only include physicians (obstetricians and gynecologists), nutritionists/dietitians, epidemiologists/methodologists, and patient/consumer representatives);
- whether or not the external stakeholder group was comprehensive (i.e., whether it was adequate to only include physicians (obstetricians and gynecologists), nutritionists/dietitians, epidemiologists/methodologists, research funders, and patient/consumer representatives);
- whether or not it was useful for us to get feedback from the report authors, local stakeholders, and external stakeholders; or if we could have abbreviated our process in some way; and
- any additional feedback.