# External Inputs

## Other Authors of 2008 Evidence Report on Gestational Diabetes who Contributed to this Project

(Contributions included review of list of gaps abstracted from 2008 evidence report with feedback and suggestions for other gaps.)

Kesha Baptiste-Roberts, Ph.D., M.P.H.

Penn State University

Hershey, PA

Shari Bolen, M.D., M.P.H.

Case Western Reserve University and MetroHealth

Cleveland, OH

Tiffany L. Gary-Webb, Ph.D.

Columbia Mailman School of Public Health

New York, NY

Sherita H. Golden, M.D., M.H.S.

Johns Hopkins University School of Medicine

Baltimore, MD

Catherine T. Witkop, M.D., M.P.H.

United States Air Force Academy

Colorado Springs, CO

## Local Stakeholders (from Johns Hopkins University)

(Contributions included online and in-person review and feedback on research questions, with suggestions for other research questions. Potential conflicts of interest were disclosed through the use of Disclosures Statements.)

Michele Beaulieu, M.S.W.

Johns Hopkins Bayview Medical Center

Baltimore, MD

Linda Dunbar, Ph.D.

Johns Hopkins HealthCare

Baltimore, MD

Edith D. Gurewitsch, M.D.

Johns Hopkins University School of Medicine

Baltimore, MD

Roxanne Jamshidi, M.D.

Johns Hopkins University School of Medicine

Baltimore, MD

Christine Mckinney, M.S.

Johns Hopkins Bayview Medical Center

Baltimore, MD

Sonal Singh, M.D., M.P.H.

Johns Hopkins University School of Medicine

Baltimore, MD

## External Stakeholders (Not from Johns Hopkins University)

(Contributions included online review and feedback on research questions, with suggestions for other research questions. These stakeholders also participated in the Delphi method of formal consensus development. Potential conflicts of interest were disclosed through the use of Disclosures Statements.)

Donald R. Coustan, M.D.

Warren Alpert Medical School of Brown University and Women and Infants Hospital of Rhode Island

Providence, RI

Erica P. Gunderson, Ph.D.

Kaiser Permanente Division of Research

Oakland, CA

Carol J. Homko, Ph.D.

Temple University School of Medicine

Philadelphia, PA

Catherine Kim, M.D., M.P.H.

University of Michigan

Ann Arbor, MI

Janet C. King, Ph.D.

Children’s Hospital Oakland Research Institute

Oakland, CA

Jeanne Mahoney, R.N., B.S.N.

American College of Obstetricians and Gynecologists

Washington, DC

Flint Porter, M.D.

University of Utah School of Medicine

Salt Lake City, UT

Samuel F. Posner, Ph.D.

Centers for Disease Control and Prevention

Atlanta, GA

Caroline Signore, M.D., M.P.H.

Eunice Kennedy Shriver National Institute of Child Health and Human Development

Rockville, MD