# Executive Summary

The Effective Health Care Program was initiated in 2005 to provide valid evidence about the comparative effectiveness of different medical interventions. The object is to help consumers, health care providers, and others in making informed choices among treatment alternatives. Through its comparative effectiveness reviews, the program supports systematic appraisals of existing scientific evidence regarding treatments for high-priority health conditions. It also promotes and generates new scientific evidence by identifying gaps in existing scientific evidence and supporting new research. The program puts special emphasis on translating findings into a variety of useful formats for different stakeholders, including consumers.

The full report and this summary are available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.

## Background

Gestational diabetes mellitus (GDM), the most common medical complication of pregnancy, is defined as carbohydrate intolerance of variable degree, with an onset or first recognition occurring during pregnancy. Studies estimate that GDM affects about 7 percent of births occurring in the United States. GDM is associated with both maternal and neonatal complications. Women with GDM are at high risk for developing noninsulin dependent (type 2) diabetes mellitus.

In 2008, the Johns Hopkins University Evidence-based Practice Center (JHU EPC) completed an Agency for Healthcare Research and Quality (AHRQ) funded evidence report on glucose management, delivery management, postpartum risk assessment, and diagnostic tests for type 2 diabetes in women with GDM. The report focused on the following four key questions (KQs):

- Key Question I. What are the risks and benefits of an oral diabetes agent (e.g., glyburide), as compared to all types of insulin, for GDM?
- Key Question II. What is the evidence that elective labor induction, cesarean delivery, or timing of induction is associated with benefits or harm to the mother and neonate?
- Key Question III. What risk factors are associated with the development of type 2 diabetes after a pregnancy with GDM?
- Key Question IV. What are the performance characteristics of diagnostic tests for type 2 diabetes in women with GDM?

The report authors made the following conclusions: (1) maternal glucose levels do not differ substantially in those treated with insulin vs. insulin analogues or oral agents; (2) average infant birth weight may be lower in mothers treated with insulin than with glyburide; (3) induction at 38 weeks may reduce the macrosomia rate, with no increase in cesarean delivery rates; (4) anthropometric measures, fasting blood glucose (FBG), and 2-hour glucose value are the strongest risk factors associated with development of type 2 diabetes; (5) FBG had high specificity, but variable sensitivity, when compared to the 75-gm oral glucose tolerance test (OGTT) in the diagnosis of type 2 diabetes after delivery.

Overall, the evidence was graded either as low strength or insufficient to address the key questions. Because of the widespread deficiencies in the literature, the research team identified broad research gaps and suggested higher quality clinical studies to address each key question. Therefore, the framework for identifying and describing research gaps identified in this report may be unique and most applicable to future reports with uniformly low or insufficient strength of evidence.

In January 2010, AHRQ requested that the JHU EPC develop and pilot test a process to identify research needs. The objective of the project was to help AHRQ establish a standard process for identifying research needs in its evidence reports and to identify research needs for the management of GDM.

## Methods

We completed an eight-step process to systematically identify research needs for the management of GDM:

### Step 1 Identification and Abstraction of Research Gaps

We reviewed the “Discussion” section and, where necessary, the “Results” section of the 2008 evidence report to identify research gaps. In addition, we abstracted gaps from the five published manuscripts derived from the report. We developed a conceptual model to illustrate the report’s key questions.

### Step 2 Feedback from Authors of 2008 Evidence Report

We contacted the authors of the report to request their individual feedback on the abstracted gaps.

### Step 3 Translation of Research Gaps into Researchable Questions

After receiving feedback from the authors of the report, we revised the gaps and translated them into researchable questions. Questions were generated using the PICO (population, intervention, comparison, and outcomes) framework. We refer to the original report’s questions as “key questions” and newly generated researchable questions as “research questions.”

### Step 4 Online and In-Person Feedback on Research Questions from Local Stakeholders

We invited a group of stakeholders from our institution to provide feedback to refine the research questions. This local group included two obstetricians/gynecologists, one nutritionist/dietitian, one epidemiologist/methodologist, and two members as proxy for the patient/consumer perspective.

Online feedback. For each research question, we asked whether it was worded clearly, the likely clinical benefit/importance of addressing it (on a 9-point scale, higher score indicating greater clinical benefit/importance), and the likely ability for researchers to conduct a study to address it (on the same scale, higher score indicating higher feasibility). These scores helped the team to refine the questions and were provided to help direct the subsequent discussion and refinement of the questions during the in-person meeting. Questions were not removed at this stage.

In-person meeting. The local stakeholders participated in a 1.5-hour in-person meeting. Our purpose for this meeting was to present a summary of the online comments and results, to present the refined research questions, and to solicit further feedback on these questions.

### Step 5 Online Feedback, Consensus Development, and Prioritization of Research Questions by External Stakeholders (Delphi Approach)

We invited a group of stakeholders from various institutions across the United States. This external group included two obstetricians/gynecologists, two nutritionists/dietitians, two epidemiologists/methodologists, two research funders, and two members as proxy for the patient/consumer perspective.

Delphi approach. We used the Delphi method for consensus development, deciding a priori that this would be repeated until consensus is reached, with no more than three rounds. In the opening round, stakeholders were asked whether each research question was worded clearly and asked to rate the likely clinical benefit/importance of each. We used these ratings to classify the clinical benefit/importance of each research question as:

- high (between 7 and 9),
- medium (between 4 and 6), or
- low (between 1 and 3).

We defined consensus as at least 75 percent of stakeholders rating clinical benefit/importance within a single category. Research questions with consensus were not retained for following rounds. For each remaining research question in the next two rounds, we provided a summary (mean, range) of the ratings of clinical benefit/importance and a synopsis of comments from the previous round.

### Step 6 Prioritization of Outcomes for Key Questions I and II

Key Questions I and II had numerous outcomes. For each of these key questions, we asked external stakeholders to rank the top three outcomes essential to include in a clinical trial to address the research questions.

### Step 7 Refinement of Final Research Questions and Development of Conceptual Models To Display Research Gaps

For each key question, we developed a conceptual model to illustrate the research questions of high clinical benefit/importance.

### Step 8 Evaluation of Process

We asked contributors to the project (authors of the 2008 evidence report, local stakeholders, and external stakeholders) to evaluate our process and the final research questions.

## Results

### Step 1 Identification and Abstraction of Research Gaps

Gaps included research in populations of diverse races/ethnicities and GDM types (diet-controlled, oral medications-requiring, insulin-requiring); and interventions and outcomes from the 2008 report. In addition to gaps specific to a key question, we abstracted general research gaps for GDM (e.g., interventions to improve compliance with postpartum screening for type 2 diabetes).

### Step 2 Feedback from Authors of 2008 Evidence Report

Five of the eight contacted authors provided the following feedback on the identified gaps. Authors suggested that more randomized controlled trials (RCTs), or for populations in whom RCTs would be particularly challenging, larger well-designed observational studies should be conducted. Authors also stressed the need for consistent definitions of outcomes across studies.

### Step 3 Translation of Research Gaps into Researchable Questions

We incorporated the feedback from the authors of the 2008 report and translated the gaps into seventeen research questions (see Appendix B). Of these questions, six, three, five, and three related to Key Questions I, II, III, and IV, respectively.

### Step 4 Online and In-Person Feedback on Research Questions from Local Stakeholders

Online feedback. We received online feedback from all local stakeholders. The ratings are summarized below:

- Key Question I (six research questions). Research Question I-1 (effectiveness and safety of any second generation sulfonylurea vs. any insulin) and research question I-2 (effectiveness and safety of metformin vs. any insulin) were rated as highest clinical benefit/importance. Research Question I-3 (comparative effectiveness and safety of any oral hypoglycemic medication [i.e., a second generation sulfonylurea or metformin] vs. any insulin) was rated most feasible for a study to be conducted.
- Key Question II (three research questions). Research Question II-1 (effectiveness and safety of elective labor induction vs. expectant management at term) was rated as highest clinical benefit/importance. Research Question II-3 (effectiveness and safety of elective labor induction or cesarean delivery vs. expectant management at term in women with insulin-requiring [class A2] GDM) was rated the most feasible for a study to be conducted.
- Key Question III (five research questions). Research Question III-1 (maternal health behaviors (e.g., breastfeeding, physical activity) as risk factors for type 2 diabetes) was rated as highest clinical benefit/importance. Research Question III-4 (maternal co-morbidities [e.g., obesity, hypertension, hypercholesterolemia] as risk factors for type 2 diabetes) was rated the most feasible for a study to be conducted.
- Key question IV (three research questions). Research Question IV-1 (accuracy of a single FBG test vs. the full 2-hour 75-gm OGTT) was rated as highest clinical benefit/importance and most feasible for a study to be conducted.

In-person meeting. Through discussions 4 questions were removed. In each case, other questions were modified to include the concepts and issues addressed in those questions. Six questions were added at this step. The wording was modified in each of the remaining questions.

### Step 5 Online Feedback, Consensus Development, and Prioritization of Research Questions by External Stakeholders (Delphi Approach)

The refined list included nineteen research questions: four, two, nine, and four related to Key Questions I, II, III, and IV, respectively (see Appendix C). We have described below the results from each round, highlighting the sixteen research questions that achieved consensus (low, medium or high clinical benefit/importance) and the three that did not achieve consensus after three Delphi rounds.

Delphi round 1. We included nineteen questions in round 1. Consensus of high clinical benefit/importance was established on the following eight questions:

- I-1. Effectiveness and safety of any second generation sulfonylurea vs. any insulin
- I-2. Effectiveness and safety of metformin vs. any insulin
- II-1. Effectiveness and safety of elective labor induction at 40 weeks vs. expectant management
- II-2. Effectiveness and safety of cesarean delivery at 40 weeks vs. expectant management
- III-1. Maternal health behaviors (e.g., breastfeeding, physical activity) as risk factors for type 2 diabetes
- III-7. Family history, gene mutations, genotypes, gene-environment interactions, epigenetic modifications, or other biomarkers as risk factors for type 2 diabetes
- III-8. Comparative effectiveness of various lifestyle interventions (e.g., diet, physical activity) for prevention of type 2 diabetes mellitus, glucose intolerance/impaired fasting glucose, and obesity
- IV-3. Comparative effectiveness of strategies or interventions to improve clinician compliance with postpartum screening guidelines for type 2 diabetes.

Delphi round 2. Eleven questions did not achieve consensus in round 1. Of these, six achieved consensus in round 2.

Consensus of high clinical benefit/importance was established on the following five questions:

- I-3. Comparative effectiveness and safety of various insulin regimens in terms of type/duration, dosing, and frequency of administration
- III-3. Maternal metabolic measures (e.g., fasting insulin levels, OGTT measures) as risk factors for type 2 diabetes
- III-4. Co-morbid conditions (e.g., advanced maternal age, obesity, hypertension) as risk factors for type 2 diabetes
- III-9. Comparative effectiveness of various educational and behavioral change strategies (e.g., patient education about diabetes risk, lactation support) for prevention of type 2 diabetes
- IV-2. Performance characteristics (sensitivity, specificity, and reproducibility) of the HbA1c test vs. the 2-hour 75-gm OGTT in screening for type 2 diabetes.

Consensus of medium clinical benefit/importance was established the following question:

- III-6. Interconception interval as a risk factor for type 2 diabetes.

Delphi round 3. Five questions did not achieve consensus in round 2. Of these, the following two questions achieved consensus high clinical benefit/importance in round 3:

- I-4. Effectiveness and safety of other hypoglycemic drug classes (e.g., thiazolidinediones) vs. any insulin or other hypoglycemic drugs
- IV-1. Performance characteristics (sensitivity, specificity, and reproducibility) of a single FBG test vs. the 2-hour 75-gm OGTT in screening for type 2 diabetes.

Research questions for which no consensus on clinical benefit/importance was established after three Delphi rounds.

- III-2. Maternal psychosocial factors (e.g., mood disorders, substance use disorders) as risk factors for type 2 diabetes
- III-5. Contraceptive method (e.g., progestin-only) as a risk factor for type 2 diabetes
- IV-4. Comparative effectiveness of health information technology interventions to track postpartum screening for type 2 diabetes in women with a history of GDM.

### Step 6 Prioritization of Outcomes for Key Questions I and II

Key Question I. Chronic diseases (e.g., obesity, type 2 diabetes) in the offspring was rated the highest among thirty outcomes. The next most important were hypertensive disorders of pregnancy (e.g., gestational hypertension, preeclampsia), medication adherence, and large for gestational age and macrosomia.

Key Question II. Cesarean delivery (including primary cesarean and repeat cesarean) and indication for cesarean delivery was rated the highest among nineteen outcomes. The next most important were birth trauma (e.g., bone fractures, brachial plexus palsy) and neonatal intensive care unit (NICU) admission.

### Step 7 Refinement of Final Research Questions and Development of Conceptual Models to Display Research Gaps

Final research questions. Through the three rounds, fifteen research questions achieved consensus of high clinical benefit/importance (see Table A) and one achieved consensus of medium clinical benefit/importance (overall consensus establishment rate=84.2 percent).

Table A Results from step 7 (final list of research questions rated as high clinical benefit/importance)

Sr. No. | Ques. Number | Final Research Questions | Clinical Benefit/Importance^***^ (Mean, Range on a Scale of 1–9)
1 | I-1 | What are the effectiveness and safety of any of the second generation sulfonylureas compared to any insulin in the treatment of gestational diabetes with regard to the following short- and long-term maternal outcomes, neonatal outcomes, and long-term offspring outcomes?^*^ | Mean=8.2 Range=7 to 9
2 | I-2 | What are the effectiveness and safety of metformin compared to any insulin in the treatment of gestational diabetes with regard to the following short- and long-term maternal outcomes, neonatal outcomes, and long-term offspring outcomes?^*^ | Mean=7.9 Range=6 to 9
3 | I-3 | What are the comparative effectiveness and safety of various insulin regimens in terms of type/duration, dosing, and frequency of administration in the treatment of gestational diabetes with regard to the following short- and long-term maternal outcomes, neonatal outcomes, and long-term offspring outcomes?^*^ | Mean=7.3 Range=6 to 9
4 | I-4 | What are the effectiveness and safety of other hypoglycemic drug classes (e.g., thiazolidinediones, DPP-4 inhibitors, GLP-1 agonists, meglitinides) compared to any insulin or other hypoglycemic drugs in the treatment of gestational diabetes with regard to the following short- and long-term maternal outcomes, neonatal outcomes, and long-term offspring outcomes?^*^ | Mean=6.9 Range=4 to 9
5 | II-1 | What are the effectiveness and safety of elective labor induction at 40 weeks compared to expectant management in women with gestational diabetes with regard to the following maternal and neonatal outcomes?^**^ [underlined: Populations of Interest:]; - All women with gestational diabetes; - Women with insulin-requiring (class A2) gestational diabetes; - Obese women with gestational diabetes; - Women with gestational diabetes with high estimated fetal weight (e.g., >4000 or >4500 gram); - Women with different parities; - Women of various races/ethnicities. | Mean=7.8 Range=6 to 9
6 | II-2 | What are the effectiveness and safety of elective cesarean delivery at 40 weeks compared to expectant management in women with gestational diabetes with regard to the following maternal and neonatal outcomes?^**^ [underlined: Populations of Interest:]; - All women with gestational diabetes; - Women with insulin-requiring (class A2) gestational diabetes; - Obese women with gestational diabetes; - Women with gestational diabetes with high estimated fetal weight (e.g., >4000 or >4500 gram); - Women with different parities; - Women of various races/ethnicities. | Mean=7.3 Range=4 to 9
7 | III-1 | What is the evidence that maternal health behaviors (e.g., breastfeeding, physical activity, diet) are associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Mean=8.1 Range=7 to 9
8 | III-3 | What is the evidence that maternal metabolic measures (e.g., fasting insulin levels, OGTT measures, HPA axis stress (subclinical hypercortisolism)) are associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Mean=7.3 Range=6 to 8
9 | III-4 | What is the evidence that co-morbid conditions (e.g., advanced maternal age, obesity, hypertension, hypercholesterolemia) are associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Mean=7.4 Range=6 to 9
10 | III-7 | What is the evidence that family history, gene mutations, genotypes, gene-environment interactions, epigenetic modifications, or other biomarkers are associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose among women with gestational diabetes? Are there differences in these associations by race or ethnic group? | Mean=7.4 Range=3 to 9
11 | III-8 | What is the comparative effectiveness of various lifestyle interventions (e.g., diet, physical activity, smoking) for prevention of type 2 diabetes, glucose intolerance/impaired fasting glucose, and obesity in women with a history of gestational diabetes? | Mean=7.7 Range=6 to 9
12 | III-9 | What is the comparative effectiveness of various educational and behavioral change strategies (e.g., patient education about diabetes risk, lactation support, diet, physical activity) for prevention of type 2 diabetes and glucose intolerance/impaired fasting glucose in women with a history of gestational diabetes? | Mean=7.3 Range=2 to 9
13 | IV-1 | What are the performance characteristics (sensitivity, specificity, and reproducibility) of a single fasting blood glucose test compared to the full 2-hour 75-gm OGTT in screening for type 2 diabetes and glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? Does the accuracy of the fasting blood glucose test compared to the full 2-hour 75-gm OGTT vary with the postpartum testing interval in screening for type 2 diabetes and glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Mean=6.7 Range=1 to 9
14 | IV-2 | What are the performance characteristics (sensitivity, specificity, and reproducibility) of the HbA1c test compared to the 2-hour 75-gm OGTT in screening for type 2 diabetes and glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? Does the accuracy of the HbA1c test compared to the full 2-hour 75- gm OGTT vary with the postpartum testing interval in screening for type 2 diabetes and glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Mean=7.9 Range=6 to 9
15 | IV-3 | What is the comparative effectiveness of strategies or interventions to improve clinician compliance with postpartum screening guidelines for type 2 diabetes and glucose intolerance/impaired fasting glucose in women with a history of gestational diabetes? | Mean=7.8 Range=5 to 9

* Outcomes for Research Questions I-1, I-2, I-3, and I-4:

Short-Term Maternal Outcomes: gestational weight gain, hypertensive disorders of pregnancy (e.g., gestational hypertension, preeclampsia), hypoglycemia, glycemic control (e.g., fasting blood glucose, 2-hr postprandial glucose), patient- reported outcomes (e.g., patient treatment preference, quality of life), medication adherence, cesarean delivery (including primary cesarean and repeat cesarean) and indication for cesarean delivery, complications of cesarean delivery (e.g., wound infection, wound dehiscence), vaginal delivery (and specify type: spontaneous or operative), perineal lacerations, postpartum hemorrhage, shoulder dystocia, and peripartum mortality

Long-Term Maternal Outcomes: postpartum weight retention, obesity, patient-reported outcomes (e.g., quality of life), development of postpartum type 2 diabetes or glucose intolerance/impaired fasting glucose, and mortality

Neonatal Outcomes: hypoxia/anoxia, birth trauma (e.g., bone fractures, brachial plexus palsy), birth weight, hyperbilirubinemia, hypoglycemia, large for gestational age and macrosomia, small for gestational age, neonatal intensive care admission, respiratory distress syndrome, and perinatal mortality

Long-Term Offspring Outcomes: infant and child growth, anthropometrics, and chronic diseases (e.g., obesity, type 2 diabetes).

** Outcomes for Research Questions II-1 and I-2:

Maternal Outcomes: cesarean delivery (including primary cesarean and repeat cesarean) and indication for cesarean delivery, complications of cesarean delivery (e.g., wound infection, wound dehiscence), vaginal delivery (spontaneous, operative), perineal lacerations, hemorrhage, patient-reported outcomes (e.g., patient preference, quality of life), length of hospital stay, pulmonary embolism, and mortality

Neonatal Outcomes: hypoxia/anoxia, birth trauma (e.g., bone fractures, brachial plexus palsy), birth weight, hyperbilirubinemia, hypoglycemia, large for gestational age and macrosomia, small for gestational age, neonatal intensive care admission, respiratory distress syndrome, and perinatal mortality.

*** We used the external stakeholders’ ratings of clinical benefit/importance to classify each research question as follows:

- high clinical benefit/importance (between 7 and 9),
- medium clinical benefit/importance (between 4 and 6), and
- low clinical benefit/importance (between 1 and 3).

We defined consensus to have been achieved if at least 75 percent (7 out of 9) of stakeholders rated clinical benefit/importance within a single category (high, medium, or low).

Abbreviations: DPP-4=dipeptidyl peptidase-4, GLP-1=glucagon-like peptide-1, HbA1c=hemoglobin A1c, HPA=hypothalamo-pituitary-adrenal, OGTT=oral glucose tolerance test.

Conceptual Models: See figures A, B, C, and D for conceptual models displaying research questions related to key questions I, II, III, and IV, respectively.

Figure A Results from step 7 (conceptual model to display research questions related to key question I (KQ-I))

Abbreviations: DPP-4=dipeptidyl peptidase-4, GLP-1=glucagon-like peptide-1.

Figure B Results from step 7 (conceptual model to display research questions related to key question II (KQ-II))

Abbreviations: EFW=estimated fetal weight.

Figure C Results from step 7 (conceptual model to display research questions related to key question III (KQ-III))

Abbreviations: HPA=hypothalamo-pituitary-adrenal, OGTT=oral glucose tolerance test.

Figure D Results from step 7 (conceptual model to display research questions related to key question IV (KQ-IV))

Abbreviations: HbA1c=hemoglobin A1c, OGTT=oral glucose tolerance test.

### Step 8 Evaluation of Process

All contributors felt that we had accomplished our objective of identifying important research questions for GDM. Additional suggested stakeholders included endocrinologists/diabetologists and patients with current/past GDM. A web-based form was the most preferred mode of participation.

## Conclusions

Using the 2008 JHU EPC evidence report on the management and postpartum followup of GDM, we developed an eight-step process for identifying and prioritizing clinically important research needs, with key input from a diverse group of stakeholders. The research needs, reflecting the breadth of the original key questions, address a variety of interventions, risk factors for development of GDM and outcomes. Questions that were specifically added through the involvement with stakeholders included the role of genetics in the development of GDM and the role of lifestyle changes in prevention, as well as questions about appropriate ways to increase patient and physician education and compliance. There did not appear to be a particular type of question that did not reach consensus or was not rated as of high clinical importance. Through this process we propose a final list of fifteen research questions, and high priority outcomes of interest, which highlight the most up-to-date research needs in the field.

There are several strengths to the process we developed. First, our research team had diverse expertise. Three of the members of the team were also part of the original report’s research team, one of which was the original report’s principal investigator. Second, we invited stakeholders from a wide range of relevant disciplines to ensure a balanced and broad perspective on research needs for GDM. Third, we used the Delphi method to achieve formal consensus development.

There are several limitations to our process for identifying research gaps. In particular, we had limited input from patients and patient liaisons. In addition, this was a fairly resource-intense process, with eight steps, including three Delphi rounds. It is possible that the same research team that just completed an evidence report may not be able to commit the time and resources to these steps. Rather, we would suggest an independent or combination independent-current evidence report team carry out this additional process.

### Lessons Learned and Future Directions

Several stakeholders agreed that more interactive approaches, such as Webinars would have been more effective in engaging multiple stakeholders from various geographical regions. We also identified the need to involve a large number of non–research-oriented clinician and patient perspectives in the process, especially related to studying patient-oriented outcomes. For this pilot we recognized certain logistical barriers to involving patients (e.g., institutional review board review, patient selection). Future projects will need to incorporate patients and their perspectives, particularly for prioritizing patient-centered outcomes. Our research team determined that each step was useful, often iterative, and built upon the previous step. However, it may be that certain steps could be abbreviated. The impact of any changes should be evaluated. We anticipate that our process could be used as is, or modified based on the evaluations, as a model for using other evidence reports to take the next step of developing research questions in areas of highest clinical importance.

We identified 15 research needs (see Table A) that were considered by a diverse group of stakeholders to be of high clinical importance. These research needs may be used by professional organizations, researchers and others as a basis for the development of a research agenda.