# Discussion

Using the 2008 JHU EPC evidence report on the management and postpartum followup of GDM, we developed an eight-step process for identifying and prioritizing clinically important research needs, with key input from a diverse group of stakeholders. The research needs, reflecting the breadth of the original key questions, address a variety of interventions, risk factors for development of GDM and outcomes. Questions that were specifically added through the involvement with stakeholders included the role of genetics in the development of GDM and the role of lifestyle changes in prevention, as well as questions about appropriate ways to increase patient and physician education and compliance. There did not appear to be a particular type of question that did not reach consensus or was not rated as of high clinical importance. Through this process we propose a final list of fifteen research questions, and high priority outcomes of interest, which highlight the most up-to-date research needs in the field.

There are several strengths to the process we developed. First, our research team had diverse expertise. Three of the members of the team were also part of the original report’s research team. In fact, one of the co-principal investigators of this project (WKN) was the principal investigator of the original report. Their insight into the report and the field of GDM enabled greater depth into the field and in the selection of stakeholders. Second, we invited stakeholders from a wide range of relevant disciplines, including social work and nutrition, to ensure a balanced and broad perspective on research needs for GDM. Each stakeholder was highly interested and committed. There were high levels of participation at each step. Third, we used the Delphi method to achieve formal consensus development.

There are several limitations to our process for identifying research gaps. In particular, we had limited input from patients and patient liaisons. We communicated with non-research nutritionists and clinicians in the local stakeholder step, but their feedback was limited by the complexity of the project and amount of information presented from the 2008 report. In fact, the social worker (a local stakeholder) proposed examining psychosocial risk factors for progression to type 2 diabetes, but this was ranked as lower priority in the Delphi rounds with external stakeholders. In addition, this was a fairly resource-intense process, with eight steps, including three Delphi rounds. It is possible that the same research team that just completed an evidence report may not be able to commit the time and resources to these steps. Rather, we would suggest an independent or combination independent-current evidence report team carry out this additional process.

Finally, we developed and completed eight steps to identify and prioritize research needs. A research or evidence gap is a topic or area for which missing or inadequate information limits the ability of reviewers to reach a conclusion on a given question. Steps 1 through 3 identified research gaps and translated these to research questions. The remaining steps identified research needs. A research need is a topic or area for which further research is needed to fill a research gap. A research gap may not be a research need if filling the gap does not help decisionmakers. There are additional steps to be completed in taking these research needs and developing a research agenda. Additional steps would include the search for new evidence that may fill the identified evidence gaps, such as an update of the search from the 2008 evidence report and a search for ongoing studies. Also needed for the development of a research agenda are decisions about appropriate study designs and the feasibility of addressing the identified research needs given local circumstances such as funding and current practice. These additional steps would involve a different process, including the participation of different stakeholders.

## Lessons Learned and Future Directions

Our team greatly learned from this process and it is an opportunity to share lessons learned. Although stakeholders generally provided positive feedback about completing web-based materials, several agreed that more interactive approaches, such as Webinars would have been more effective in engaging multiple stakeholders from various geographical regions. We also identified the need to involve a large number of non-research-oriented clinician and patient perspectives in the process, especially related to studying patient-oriented outcomes. For this pilot we recognized certain logistical barriers to involving patients, such as institutional review board (IRB) review, selection of a representative sample of patients, and the conduct of qualitative interviews. An alternative strategy for future research gaps identification projects might be to include former patients referred or recommended by advocacy organizations, such as but not limited to the American Diabetes Association (ADA), American College of Obstetricians and Gynecologists (ACOG), and the March of Dimes. Future projects will need to incorporate patients and their perspectives, particularly for prioritizing patient-centered outcomes of interest. One stakeholder questioned whether we needed all eight steps to reach the same conclusions. Our research team determined that each step was useful, often iterative, and built upon the previous step. Moreover, each step helped to ensure a broad, comprehensive, and unbiased summary of current research gaps. However, it may be that certain steps could be abbreviated. The impact of any changes should be evaluated.