# Background

Gestational diabetes mellitus (GDM), the most common medical complication of pregnancy, is defined as carbohydrate intolerance of variable degree, with an onset or first recognition occurring during pregnancy.1 Population-based studies estimate that GDM affects about 200,000 (7 percent) of the over 4 million births occurring annually in the United States.2 GDM is associated with both maternal and neonatal complications.3–5 Furthermore, women with GDM are at high risk for developing non-insulin dependent (type 2) diabetes mellitus. In a large Canadian cohort, almost 20 percent of women with GDM developed type 2 diabetes within nine years of pregnancy.6

In 2008, the Johns Hopkins University Evidence-based Practice Center (JHU EPC) completed an Agency for Healthcare Research and Quality (AHRQ) funded evidence report on glucose management, delivery management, postpartum risk assessment, and diagnostic tests for type 2 diabetes in women with GDM.7 The report focused on the following four key questions (see Table 1): (I) What are the risks and benefits of an oral diabetes agent (e.g., glyburide), as compared to all types of insulin, for GDM?; (II) What is the evidence that elective labor induction, cesarean delivery, or timing of induction is associated with benefits or harm to the mother and neonate?; (III) What risk factors are associated with the development of type 2 diabetes after a pregnancy with GDM?; (IV) What are the performance characteristics of diagnostic tests for type 2 diabetes in women with GDM?

Table 1 Original key questions from 2008 evidence report on gestational diabetes

Key Question I (KQ-I) What is the evidence for the risks and benefits of oral diabetes agents (e.g., second-generation sulfonylureas and metformin), as compared to all types of insulin, for both the mother and neonate in the treatment of women with gestational diabetes?; a. How does maternal outcome vary based on the level of glucose at the initiation of a medication?; b. How does neonatal outcome vary based on the level of glucose at the initiation of a medication?; [underlined: Maternal outcomes:] cesarean delivery, glycemic control (FBG, 1-hr and 2-hr postprandial glucose (PPG)), hemorrhage, hypoglycemia, operative vaginal delivery, perineal tears, preeclampsia, weight [underlined: Neonatal outcomes:] anoxia, birth trauma, birth weight, congenital malformations, hyperbilirubinemia, hypoglycemia, LGA, macrosomia, mortality, neonatal intensive care admissions, respiratory distress syndrome, shoulder dystocia, SGA.
Key Question II (KQ-II) What is the evidence that elective cesarean delivery or the choice of timing of induction in women with gestational diabetes results in beneficial or harmful maternal and neonatal outcomes?; a. What is the evidence for elective cesarean delivery at term, as compared to an attempt at vaginal delivery (spontaneous or induced) at term, with regard to beneficial or harmful maternal and neonatal outcomes in gestational diabetes?; i. cesarean vs. spontaneous labor and vaginal delivery; ii. cesarean vs. induced labor and vaginal delivery; iii. cesarean vs. any attempt at vaginal delivery at term; b. What is the evidence for labor induction at 40 weeks, as compared to labor induction at an earlier gestational age (less than 40 weeks) or spontaneous labor, with regard to beneficial or harmful maternal and neonatal outcomes in gestational diabetes?; i. labor induction at less than 40 weeks vs. labor induction at 40 weeks; ii. labor induction at 40 weeks vs. spontaneous labor; iii. labor induction at less than 40 weeks vs. spontaneous labor; c. How is the EFW related to outcomes of management of gestational diabetes with elective cesarean delivery or the timing (i.e., gestational age range) of labor induction?; d. How is gestational age related to outcomes of management of gestational diabetes with elective cesarean delivery or the choice of timing (i.e., gestational age range) of labor induction?; [underlined: Maternal outcomes:] cesarean delivery, hemorrhage, infection, operative vaginal delivery, perineal tears [underlined: Neonatal outcomes:] anoxia, birth trauma, birth weight, congenital malformations, hyperbilirubinemia, hypoglycemia, LGA, macrosomia, mortality, neonatal intensive care admissions, respiratory distress syndrome, shoulder dystocia, SGA.
Key Question III (KQ-III) What risk factors, including but not limited to family history, physical activity, pre-pregnancy weight, and gestational weight gain, are associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes?
Key Question IV (KQ-IV) What are the performance characteristics (sensitivity, specificity, and reproducibility) of tests for diagnosing type 2 diabetes after pregnancy in patients with a history of gestational diabetes? Are there differences in the performance characteristics of the test results based on subgroup analysis?

Abbreviations: EFW=estimated fetal weight, FBG=fasting blood glucose, LGA=large for gestational age, PPG=postpartum glucose, SGA=small for gestational age

The report authors identified 45 articles and made the following conclusions: (1) maternal glucose levels do not differ substantially in those treated with insulin vs. insulin analogues or oral agents; (2) average infant birth weight may be lower in mothers treated with insulin than with glyburide; (3) induction at 38 weeks may reduce the macrosomia rate, with no increase in cesarean delivery rates; (4) anthropometric measures, fasting blood glucose (FBG), and 2-hour glucose value are the strongest risk factors associated with development of type 2 diabetes; (5) FBG had high specificity, but variable sensitivity, when compared to the 75-gm oral glucose tolerance test (OGTT) in the diagnosis of type 2 diabetes after delivery.

Overall, the evidence was graded either as low strength or insufficient to address the key questions. Because of the widespread deficiencies in the literature, the authors noted that it was challenging to identify very specific gaps to target future research. Rather, the research team identified broad research gaps and suggested higher quality clinical studies to address each key question. Therefore, the framework for identifying and describing research gaps identified in this report may be unique and most applicable to future reports with uniformly low or insufficient strength of evidence.

## Objective

In January 2010, AHRQ requested that the JHU EPC develop and pilot test a process to identify research needs. The objectives of the project were: (1) to help AHRQ establish a standard process for identifying research needs in its evidence reports and (2) to identify and prioritize future research needs for the management of gestational diabetes.