# Appendixes

Appendix A Results from Step 1 (Identification and Abstraction of Research Gaps from Evidence Report (2008) and Five Published Manuscripts) and Step 2 (Feedback from Authors of 2008 Evidence Report)

Appendix B Results from Step 3 (Translation of Research Gaps into Researchable Questions) and Step 4 (Online and In-Person Feedback on Research Questions from Local Stakeholders)

Appendix C Results from Step 5 (Online Feedback, Consensus Development, and Prioritization of Research Questions by External Stakeholders (Delphi Approach))

Appendix D Results and Comments from External Stakeholders (Delphi Round 1)

Appendix E Results and Comments from External Stakeholders (Delphi Round 2)

Appendix F Results and Comments from External Stakeholders (Delphi Round 3)

Appendix G Results from Step 8 (Evaluation of Entire Process by Evidence Report Authors and Local Stakeholders)

Appendix H Results from Step 8 (Evaluation of Entire Process by External Stakeholders)