# Results from Step 8 (Evaluation of Entire Process by External Stakeholders)

No. | Questions | External Stakeholder 1 | External Stakeholder 2 | External Stakeholder 3 | External Stakeholder 4 | External Stakeholder 5 | External Stakeholder 6 | External Stakeholder 7 | External Stakeholder 8 | External Stakeholder 9
1 | Did you have adequate information to effectively participate? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
2 | Which mode of participation would you have preferred? | Web-based feedback | Web-based feedback | Web-based feedback | Web-based feedback that allows users to save a partially completed survey and come back at another time. This must be possible because I have participated in other web-based surveys that allow this. | Web-based feedback | Web-based feedback | Web-based feedback | Web-based feedback | Web-based feedback
3 | Looking at the final research questions, do you feel that we accomplished our objective? | I thought you accomplished your objective. It was possible to start from an even broader base—for example, the importance of genomics for GDM or consideration of diagnostic criteria in the context of strain on existing resources. I suppose the drawback of that would have been that it would have been too broad and no consensus would have been reached. | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
4 | Are there any final research questions that you would rephrase? | Yes. The use of the term “accuracy” in comparing FBG and 2-hour OGTTs could be rephrased—FBGs will always be less sensitive and specific if OGTT is used as the gold standard. The only way to settle it is to make the criteria outcomes-based. | No | Yes. IV-1 and IV-2 are dependent on patient compliance even more than performance characteristics. The longer the test and the more distant from the delivery the poorer the compliance. | No | No | No | Yes. In research question I-4, the comparison is between other hypoglycemic drug classes to other hypoglycemic drugs. Perhaps this is clear to all except for me that drugs and drug classes are two different things. | No | No
5 | Was the composition of the local group of 6 stakeholders comprehensive? (i.e., was it adequate to include physicians(obstetricians and gynecologists), nutritionists/dietitians, epidemiologists/methodologists, and patient/consumer representatives?) | Yes | No. I suggest including endocrinologists who care for women with diabetes. | Yes | Yes | Yes | Yes | No. Why weren't nephrologists included? This seems like a specialty that is missing. | I am unable to respond to this question. | Yes
6 | Was the composition of the external group of 10 stakeholders comprehensive? (i.e., was it adequate to include physicians(obstetricians and gynecologists), nutritionists/dietitians, epidemiologists/methodologists, research funders, and patient/consumer representatives?) | Yes | No. As with the internal group, would have included endcrinologists who care for pregnant women with diabetes. | Yes | No. Diabetologist input would have been a good idea. | Yes | Yes | No. Again, where were the nephrologists? Perhaps they provide care at a more advanced stage and aren't involved with primary prevention. | Yes | Yes
7 | Could we have abbreviated our process in some way? (i.e., was it necessary to get feedback from the 2008 evidence report authors, local stakeholders, and external stakeholders?) | No | No | No | Yes. I'm not sure why a group of local stakeholders was necessary since the object of the process was nationally usable research questions. Perhaps it was used as a focus group, in which case the only reason for it to be local was convenience. | No | No | No | No | No
8 | Do you have any additional feedback on our process or on the final research questions? | Yes. Nice job, obviously a lot of thought and hard work went into this. | No | No | Yes. Web-based instrument used should have allowed user to interrupt session and come back. | No | Yes. This process was very effective and efficient. Couldn't have been done better!! | Yes. Was consensus achieved after 3 rounds? In your final report you might consider documenting which ones didn't reach consensus. These are potentially the most controversial or debated in the field. | No | Yes. I enjoyed being a part of this and it seems to be an efficient yet nicely thorough method for decision- making. Thank you for including me. My only "complaint" would be the limitations of the online tool: not being able to save and return, and not being able to see any subsequent questions until all previous questions were answered. Having a simple way to download or print out the surveys for offline work/thought would have been helpful.

Abbreviations: FBG=fasting blood glucose, GDM=gestational diabetes mellitus, OGTT=oral glucose tolerance test.