# Results from Step 8 (Evaluation of Entire Process by Evidence Report Authors and Local Stakeholders)

No. | Questions | Report Author 1 | Report Author 2 | Report Author 3 | Report Author 4 | Report Author 5 | Local Stakeholder 1 | Local Stakeholder 2 | Local Stakeholder 3 | Local Stakeholder 4 | Local Stakeholder 5 | Local Stakeholder 6
1 | Did you have adequate information to effectively participate? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
2 | Which mode of participation would you have preferred? | Web- based feedback | Web-based feedback | Web-based feedback | Telephone | Web-based with an option to participate in in-person or telephone meetings during the process. | In-person | Web-based feedback | Web-based feedback | Web-based feedback | I thought the combination of a web-based and in-person feedback was good. Web- based survey was more time effective, but the in-person meeting allowed for richer conversation and feedback. | In-person
3 | Looking at the final research questions, do you feel that we accomplished our objective? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
4 | Are there any final research questions that you would re- phrase? | Yes. Research questions III-7. What is the evidence that family history, gene- environment inter-actions, and epigenetic alterations are associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose among women with gestational diabetes? | Yes. I thought research questions IV-1 and IV-2 could be combined into one question(i.e., comparison of FBG vs HbA1c vs 2-hour PPG) but am ok with separate. | No | No | No | Yes. III-1. Suggest that since the question has a negative connotation as currently written and implies a directionality of effect of these behaviours (increased risk) just as this is implied in question below it. For example, if exercise lowers the risk of type 2 diabetes, I am unsure if this question would be the best. | No | No | No | Yes. Only would add birth defects as a neonatal outcome for questions I-1 through I-4. | No
5 | Was the composition of the local group of 6 stakeholders comprehensive? (i.e. was it adequate to include physicians(obstetricians and gynecologists), nutritionists/dietitians, epidemiologists/methodologists, and patient/consumer representatives?) | Yes | Yes | Yes | No. One other group to consider input from would be neonatologists as they could provide insight into which neonatal outcomes are associated with the greatest moridibity/mortality in the newborn period. Otherwise, the relevant stakeholders were included. | Yes | Yes | Yes | No. You should consider including patients either with GDM now or history of GDM for their perspective on the importance of these questions. | Yes | Yes | Yes
6 | Was the composition of the external group of 10 stakeholders comprehensive? (i.e. was it adequate to include physicians(obstetricians and gynecologists), nutritionists/dietitians, epidemiologists/methodologists, research funders, and patient/consumer representatives?) | Yes | Yes | Yes | No. Similar to my answer to the previous question, I would have suggested including neonatology interests. | Yes | Yes | Yes | No. Same as above. | Yes | Yes | Yes
7 | Could we have abbreviated our process in some way? (i.e. was it necessary to get feedback from the 2008 evidence report authors, local stakeholders, and external stakeholders? ) | No | No | No | No | No | No | No | No | No | No | No
8 | Do you have any additional feedback on our process or on the final research questions? | No | Yes. It is probably too late to specify this but as I looked at research questions related to KQ-IV, I was struck that we didn't include any outcomes related to patient satisfaction/adherence with postpartum testing. Anyways, sounds like it is too late to vet that question. | No | No | Yes. Would only recommend that if this process is implemented, the identification of research needs occurs at the time of the evidence report or immediately following preparation of the evidence report. | Yes. The space for typing comments on this survey is limited. | No | No | No | No | Yes. I was disppointed that the psychosocial and disparity factors were not part of final research questions. I wonder if the group had a greater percentage of consumer representatives that you would get additional questions to explore.

Abbreviations: FBG=fasting blood glucose, GDM=gestational diabetes mellitus, HbA1c=hemoglobin A1c, OGTT=oral glucose tolerance test, PPG=postpartum glucose.