# Results and Comments from External Stakeholders (Delphi Round 3)

Research Question Number | Research Question | Sub-question(s) | Stakeholder 1 | Stakeholder 2 | Stakeholder 3 | Stakeholder 4 | Stakeholder 5 | Stakeholder 6 | Stakeholder 7 | Stakeholder 8 | Stakeholder 9 | Result Mean | Result Lower Range | Result Upper Range
I-4 | What are the effectiveness and safety of other hypoglycemic drug classes (e.g. thiazolidinediones, DPP-4 inhibitors, GLP-1 agonists, meglitinides) compared to any insulin or other hypoglycemic drugs in the treatment of gestational diabetes with regard to the following short- and long-term maternal outcomes, neonatal outcomes, and long- term offspring outcomes? | Question A: Is this research question clearly worded? | Yes | Yes | No. The use of the term "or other hypoglycemic drugs " in the second line is confusing because you are comparing with "other hypoglycemic drug classes". | Yes | Yes | Yes | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 4 | 7 | 5 | 8 | 7 | 7 | 7 | 8 | 6.9 | 4 | 9
| | Question C: Rationale for above rating | - | I am still not clear why we would want to move forward with other oral agents when the long-term impact of metformin and glyburide on maternal and neonatal outcomes is still not known. Should focus on agents currently being utilized clinically. | - | I am relatively neutral because I believe that so much needs to be done with glyburide, metformin, and alphaglucosidase inhibitors which are already being used that I hate to see attention and resources diverted from them. On the other hand, if the meds noted do not turn out to be safe or effective, then we should move on to the others after animal studies better address the issue of transplacental transfer and fetal exposure. | - | - | - | - | - | N/A | N/A | N/A
III-2 | What is the evidence that maternal psychosocial factors(e.g. mood disorders, substance use disorders, eating disorders, stress) are associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | Yes | Yes | Yes | Yes | No. The suggested list of psychosocial factors is really psychological rather than social. The other problem is that there is no time frame—within five years, 50 years? Needs clarification. | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 7 | 6 | 7 | 5 | 8 | 6 | 5 | 5 | 5 | 6.0 | 5 | 8
| | Question C: Rationale for above rating | - | - | Understanding the relationship between psychosocial and metabolic factors may further guide prevention strategies and identify those at risk. | Worthwhile questions but not directly related to GDM...applicable to diabetes even without history of GDM. | - | - | - | - | - | N/A | N/A | N/A
III-5 | What is the evidence that contraceptive method (e.g. progestin-only) is associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | No. Change to "progestin-only oral contraceptive pills" or "progestin- implant" OR "progestin injection". | Yes | Yes | Yes | Yes | Yes | No. See below. | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 8 | 7 | 6 | 8 | 5 | 5 | 5 | 5 | 4 | 5.9 | 4 | 8
| | Question C: Rationale for above rating | - | Prevention of type 2 diabetes is of critical importance. | - | - | - | - | Timeframe is an issue here---developing diabetes in what time frame, after what duration of using the contraceptive method (ever use, after at least 5 years of use), it appears that it is implied as hormonal contraceptives is the contraceptive of interest. There are other contraceptive methods in the generic definition. | - | - | N/A | N/A | N/A
IV-1 | What are the performance characteristics(sensitivity, specificity, and reproducibility) of a single fasting blood glucose test compared to the full 2-hour 75-gm OGTT in screening for type 2 diabetes and glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? Does the accuracy of the fasting blood glucose test compared to the full2-hour 75-gm OGTT vary with the postpartum testing interval in screening for type 2 diabetes and glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 1 | 7 | 9 | 7 | 7 | 7 | 6 | 8 | 8 | 6.7 | 1 | 9
| | Question C: Rationale for above rating | I think the question has been answered. | The data indicate that the majority of women with a history of GDM do not get followup testing. If performance of FBG was found to be adequate, it could potentially substantially increase the number of women who are tested. | This is very clear and extremely important to determine in light of the difficulty to "capture" postpartum women for a 2 hr OGTT and also to determine the earliest an accurate postpartum screening can be done and followup initiated prior the loss of insurance for many women on Medicaid. | The first of the two questions is not specific to GDM. | - | - | - | - | - | N/A | N/A | N/A
IV-4 | What is the comparative effectiveness of different health information technology interventions to track postpartum screening for the development of type 2 diabetes mellitus and glucose intolerance/impaired fasting glucose in women with a history of gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | Yes | Yes | Yes | No. The linkage of different health information technology interventions with development of type 2 diabetes is unclear. Could a brief introductory rationale be provided? That would help identify what interventions could be considered. | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 5 | 6 | 8 | 7 | 5 | 5 | 6 | 7 | 3 | 5.8 | 3 | 8
| | Question C: Rationale for above rating | It would be nice if examples of specific interventions could be provided, but understandable if they cannot. What is there besides an electronic medical record? | I feel the priority should be on getting women tested and then move to better tracking methods. | Essential for both internal office tracking and in reminding women of their need for followup. It would be great to have a texting program for postpartum reminders. | - | - | - | - | - | - | N/A | N/A | N/A
Additional | - | Do you have any general comments? | - | - | Thank you for the opportunity to participate. The process was painless and feedback educational. | - | - | - | - | - | - | N/A | N/A | N/A

Abbreviations: DPP-4=Dipeptidyl Peptidase-4, FBG=fasting blood glucose, GDM=gestational diabetes mellitus, GLP-1= Glucagon-Like Peptide-1, OGTT=oral glucose tolerance test.