# Results and Comments from External Stakeholders (Delphi Round 2)

Research Question Number | Research Question | Sub- question(s) | Stakeholder 1 | Stakeholder 2 | Stakeholder 3 | Stakeholder 4 | Stakeholder 5 | Stakeholder 6 | Stakeholder 7 | Stakeholder 8 | Stakeholder 9 | Result Mean | Result Lower Range | Result Upper Range
I-3 | What are the comparative effectiveness and safety of various insulin regimens in terms of type/duration, dosing, and frequency of administration in the treatment of gestational diabetes with regard to the following short- and long-term maternal outcomes, neonatal outcomes, and long- term offspring outcomes? | Question A: Is this research question clearly worded? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No. The distinction between short- and long-term outcomes is unclear in this context. I would recommend more specific terms that could include “pregnancy” or “perinatal” outcomes and “postpartum” maternal outcomes for women instead of short- and long- term. The term long-term would encompass the years after delivery and incident type 2 diabetes years in mid life or later rather than solely during the postpartum period. I also recommend that a postpartum maternal outcome is obesity in addition to postpartum weight retention. | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 7 | 6 | 9 | 7 | 7 | 8 | 7 | 8 | 7 | 7.3 | 6 | 9
| | Question C: Rationale for above rating | - | - | - | - | - | - | - | The last phrase is too long and awkward, “following short- and long- term maternal outcomes, neonatal outcomes, and long-term offspring outcomes”. I suggest that you state, “perinatal and postpartum maternal outcomes, and the neonatal and childhood offspring outcomes”. | - | N/A | N/A | N/A
I-4 | What are the effectiveness and safety of other hypoglycemic drug classes (e.g. thiazolidinediones, DPP-4 inhibitors, GLP1 agonists, meglitinides) compared to any insulin or other hypoglycemic drugs in the treatment of gestational diabetes with regard to the following short- and long-term maternal outcomes, neonatal outcomes, and long- term offspring outcomes? | Question A: Is this research question clearly worded? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No. Same comments as the previous | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 8 | 3 | 9 | 7 | 7 | 8 | 6 | 8 | 4 | 6.7 | 3 | 9
| | Question C: Rationale for above rating | - | Should address the safety and effectiveness of the two oral agents being clinically utilized before we move forward with other agents. | - | - | - | - | - | Instead of this long wording “short- and long-term maternal outcomes, neonatal outcomes, and long-term offspring outcomes”, I suggest that you state, I suggest that you state, “perinatal and postpartum maternal outcomes, and the neonatal and childhood offspring outcomes”. | - | N/A | N/A | N/A
III-2 | What is the evidence that maternal psychosocial factors (e.g. mood disorders, substance use disorders, eating disorders, stress) are associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | No. Make it “tobacco and substance use disorders”. | Yes | Yes | Yes | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 8 | 6 | 8 | 4 | 4 | 6 | 8 | 5 | 5 | 6.0 | 4 | 8
| | Question C: Rationale for above rating | Understudied and probably important as these are common factors. In an unrelated comment, the ranking of “3 most important” outcomes is somewhat artificial--of course you’d study more. I also have suspicion that “fundable” outcomes (“hard” outcomes like cesarean delivery, other “medical” complications) might differ from other outcomes that might actually have greater influence upon complication rates in the ‘real world’, such as patient preferences. If a patient doesn’t want 3 time daily injectable insulin, would a slight decrease in cesarean section rates be enough to convince her. | No comments | It is unclear whether it is the risk factor itself or the maternal response to the risk factor that increases the incidence of type 2 diabetes following GDM and that helps decide targeting patient’s at risk and patient management. | I’m not sure this question is related only to pregnancy; same question could be posed regarding the development of diabetes in males, or females who have never been pregnant. | No comments | No comments | No comments | No comments | No comments | N/A | N/A | N/A
III-3 | What is the evidence that maternal metabolic measures (e.g. fasting insulin levels, OGTT measures, HPA axis stress (subclinical hypercortisolism)) are associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | No. Maternal metabolic measures during pregnancy or after pregnancy? If after pregnancy, is there any reason to think they differ from women in general? We know that insulin and glucose are associated with diabetes risk and are in the pathway to diabetes risk. HPA stress axis is important but sticks out as the more novel factor that is in a different category than the others. Consider separating HPA out, or dumping fasting insulin and glucose levels. | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 7 | 7 | 8 | 8 | 8 | 7 | 8 | 6 | 7 | 7.3 | 6 | 8
| | Question C: Rationale for above rating | - | - | Needed to determine who is at most risk and in need of close followup. | - | - | - | - | - | - | N/A | N/A | N/A
III-4 | What is the evidence that co-morbid conditions (e.g. advanced maternal age, obesity, hypertension, hypercholesterolemia) are associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | No. How about adding, “assisted reproduction” or “fertility procedures” or some such? | Yes | Yes | Yes | Yes | Yes | Yes | No. I suggest that these time periods be specified because it is important that each is specifically recognized as important. Currently these conditions are not being advocated prior to pregnancy. Other conditions before pregnancy that are not recognized include hyperglycemia or impaired fasting glucose and glucose intolerance. | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 7 | 6 | 8 | 8 | 7 | 6 | 8 | 8 | 7.4 | 6 | 9
| | Question C: Rationale for above rating | The order in which these factors unfold is important. this was a big focus of the GDM Pasadena conference this year--more specifically, many of the bench presentations focused on lipids and how this predicts future glucose tolerance, and many of the other presentations focused on how obesity predicted perinatal complications. | - | For followup, women with comorbid conditions are more likely to receive postpartum followup and less likely to slip through the cracks. | - | - | - | - | It is important to - specify that each period is important for assessing risk. I do not agree with the suggestion to make this generic. We do not want the focus to be on the postpartum period only. Currently, these comorbid conditions are not measured routinely before pregnancy, but should be assessed during the intercurrent period. | - | N/A | N/A | N/A
III-5 | What is the evidence that contraceptive method (e.g. depo- provera) is associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | No. Depo is not a good example. You may want to use - hormonal contraception or combined contraception pills. | Yes | Yes | Yes | Yes | Yes | Yes | No. Add to the list of diseases at risk of developing... “other cardiometabolic diseases (i.e. the metabolic syndrome)”. | No. Shouldn’t use trade name for drug, substitute depot medroxypregesterone acetate. | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 8 | 7 | 8 | 8 | 3 | 5 | 5 | 4 | 3 | 5.7 | 3 | 8
| | Question C: Rationale for above rating | - | Moving forward the prevention of diabetes is critical. If true, solution is relatively straight forward. | - | - | - | - | - | - | - | N/A | N/A | N/A
III-6 | What is the evidence that the inter- conception interval is associated with the risk of developing type 2 diabetes or glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No. Add to the list of diseases to risk of developing... “other cardiometabolic diseases (i.e. the metabolic syndrome)”. | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 8 | 5 | 6 | 6 | 2 | 5 | 6 | 4 | 6 | 5.3 | 2 | 8
| | Question C: Rationale for above rating | - | - | - | - | - | - | - | - | - | N/A | N/A | N/A
III-9 | What is the comparative effectiveness of various educational and behavioral supportive strategies (e.g. patient education about diabetes risk, lactation support) to prevent type 2 diabetes mellitus and glucose intolerance/impaired fasting glucose in women with a history of gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No. Add to the list of diseases to prevent... “other cardiometabolic diseases (i.e. the metabolic syndrome)”. | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 8 | 8 | 8 | 2 | 7 | 7 | 9 | 8 | 7.3 | 2 | 9
| | Question C: Rationale for above rating | Such a demonstration of effectiveness might lead to insurance companies reimbursing for these services. | - | - | - | A more important question would be how they affect fasting and postprandial glucose levels. | - | - | Delete the word “supportive” strategies, and replace with “change” strategies. In the list, I would include: (e.g., disease risk, dietary, physical activity, and lactation). These are appropriate to include since the word “innovative” was removed. Also, if the other questions expand disease risk beyond type 2 diabetes mellitus then should consider adding those endpoints. | - | N/A | N/A | N/A
IV-1 | What are the performance characteristics (sensitivity, specificity, and reproducibility) of a single fasting blood glucose test compared to the full 2-hour 75-gm OGTT in screening for type 2 diabetes and glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? Does the accuracy of the fasting blood glucose test compared to the full 2-hour 75-gm OGTT vary with the postpartum testing interval in screening for type 2 diabetes and glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | No. Consider using the terms reliability, precision, and accuracy rather than sensitivity and specificity-- we already know that sensitivity is lower with FBG. | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 6 | 8 | 9 | 6 | 7 | 7 | 6 | 4 | 6 | 6.6 | 4 | 9
| | Question C: Rationale for above rating | Is there a reason that the performance characteristics of these tests would vary from the performance characteristics of other populations? Age might make an impact, but I’m not sure about others. If not, the impact of answering this question (FBG vs. OGTT) might be limited--we already know that FBG is less sensitive and more reliable as well as more precise. | - | Because pregnancy Medicaid coverage ends at 8 to 9 weeks postpartum and because low income women are a high risk population for GDM and type 2 diabetes, the availability of accurate testing at the earliest possible date postpartum is of utmost importance. | I’m not sure this question should be specific to former GDMs. It is a very important question in general for testing for prediabetes and diabetes. | - | - | - | - | - | N/A | N/A | N/A
IV-2 | What are the performance characteristics (sensitivity, specificity, and reproducibility) of the HgBA1c test compared to the 2- hour 75-gm OGTT in screening for type 2 diabetes and glucose intolerance/impaired fasting glucose following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No. Should include the followup question as in IV-1. | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 8 | 9 | 7 | 8 | 8 | 6 | 9 | 7 | 7.9 | 6 | 9
| | Question C: Rationale for above rating | This is particularly important with the new ADA recommendations. | - | Same comment as previous question. An accurate test that can not be done because the woman is no longer insured is unacceptable. | Not specific to former GDMs. The question of an appropriate HgbA1c cutoff for prediabetes is important for all testing situations. | - | - | - | - | - | N/A | N/A | N/A
IV-4 | What is the comparative effectiveness of different health information technology interventions to track postpartum screening for the development of type 2 diabetes mellitus and glucose intolerance/impaired fasting glucose in women with a history of gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | No. After “health information technology interventions” mention “including social media”. | Yes | Yes | Yes | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 5 | 6 | 9 | 7 | 2 | 7 | 7 | 6 | 7 | 6.2 | 2 | 9
| | Question C: Rationale for above rating | - | - | Use of text messaging or ‘Facebook’ for engaging, reminding, and tracking women who had GDM needs to be assessed. | - | - | - | - | - | - | N/A | N/A | N/A
Additional | - | Do you have any general comments? | I mentioned earlier that choosing 3 outcomes feels too restrictive. | - | - | The length of this one was much more user- friendly and I don’t object to having to do it all in one sitting. | - | - | - | - | - | N/A | N/A | N/A

Abbreviations: ADA=American Diabetes Association, FBG=fasting blood glucose, GDM=gestational diabetes mellitus, HPA=hypothalamo-pituitary-adrenal, OGTT=oral glucose tolerance test.