# Results and Comments from External Stakeholders (Delphi Round 1)

Research Question Number | Research Question | Sub- question(s) | External Stakeholder 1 | External Stakeholder 2 | External Stakeholder 3 | External Stakeholder 4 | External Stakeholder 5 | External Stakeholder 6 | External Stakeholder 7 | External Stakeholder 8 | External Stakeholder 9 | Result Mean | Result Lower Range | Result Upper Range
I-1 | What is the effectiveness and safety of any of the second generation sulfonylureas compared to any insulin in the treatment of gestational diabetes with regard to the following maternal, neonatal, and long- term offspring outcomes? | Question A: Is this research question clearly worded? | No. Consider dividing maternal outcomes into short-term and long- term, as you did for neonatal and long-term offspring outcomes. | Yes | No. Restate and reorder maternal outcomes. If medication adherence is not kept, none of the other outcomes are valid. Follow with glycemic control, patient reported outcomes, pregnancy- related issues, then delivery issues, and end with mortality. | Yes | Yes | Yes | Worded clearly. I have some suggestions as to things that are missing. Effectiveness and safety are mentioned, what about efficacy? If safety is being investigated I would expect efficacy to also be included. I expect that prediabetes as well as diabetes are included in the postpartum outcomes for the mother. Should outcomes for neonate include early/late preterm? | No. Neonatal outcomes - need to list macrosomia only once (delete second reference after small for gestational age). Define “macrosomia” specifying birth weight cutoff that refers to term births. Define the interval for “postpartum” type 2 diabetes—<12 months? Add postpartum weight retention to maternal outcomes. | No. I think it should be ‘What are’, not ‘What is...’ For neonatal outcomes, specify the period of interest for ‘mortality’: I would suggest ‘perinatal’ mortality, to incorporate the outcome of stillbirth. Also, suggest broadening the outcome of ‘anoxia,’ as lesser degrees of oxygen deprivation are of relevance. Perhaps ‘hypoxia/anoxia’ | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 9 | 9 | 8 | 7 | 8 | 7 | 9 | 8 | 8.2 | 7 | 9
| | Question C: Rationale for above rating | The long-term outcomes have not been studied as well as short-term outcomes, for obvious reasons (difficult to have adequate retention of cohort). | The practice of utilizing oral agents to treat GDM is widespread. Without robust evidence regarding their impact on the health of the neonates, this widespread use is concerning. | This question seems to be a central basis for the study. | If a second generation sulfonylurea is safe and beneficial for mother and offspring, treatment would be less onerous and compliance is likely to improve. I believe that the biggest question is safety. Since glyburide crosses the placenta according to a recent study which found low levels of glyburide in cord blood (but cord levels were 70% of the low levels in maternal blood measured simultaneously), we need to know whether fetal and long-term effects are good, bad, or neutral. Measurements of glucose disappearance curves in neonates exposed and not exposed in utero may be helpful. The biggest concern is in-utero programming, and current studies really do not address that ... it will take very long-term studies to do so. | The question has been asked before but only in a small number of studies. An RCT comparing oral agents and insulin regimens would be important. | Research is very important since a good outcome for oral agents would provide an alternative for insulin. | - | Perinatal and long-term outcomes for women and their offspring are necessary to develop evidence- based recommendations of treatments during GDM pregnancy. | - | N/A | N/A | N/A
I-2 | What is the effectiveness and safety of metformin compared to any insulin in the treatment of gestational diabetes with regard to the following maternal, neonatal, and long- term offspring outcomes? | Question A: Is this research question clearly worded? | Yes, although please see comments for the previous questions. | Yes | No. Reword maternal outcome as in Question 1 with patient adherence first followed by pregnancy considerations and ending with delivery and mortality. | Yes | Yes | No. Macrosomia is listed twice - once with large for gestational age and once alone. | No. Same as 1-1 | No. Comments similar to previous page. | No. Identical comments as for Question I-1. | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 9 | 8 | 8 | 6 | 8 | 6 | 9 | 8 | 7.9 | 6 | 9
| | Question C: Rationale for above rating | Metformin has been shown to delay cardiovascular disease or macrovascular complications but given outside of pregnancy; treatment during pregnancy would be interesting. | Impact on neonatal outcomes and particularly long-term outcomes in needed. | - | Answer would be similar to that for glyburide in question A, except that metformin crosses the placenta to a much greater extent than glyburide. Being an insulin sensitizer, metformin might also have long-term metabolic effects on the offspring. | See prior comment. | - | - | Metformin safety and efficacy has not been firmly established based on available studies. | - | N/A | N/A | N/A
I-3 | What is the effectiveness and safety of individual insulin regimens (e.g. long or intermediate acting) or combination regimens (e.g. long + short-acting) compared to other insulin regimens or combination regimens in the treatment of gestational diabetes with regard to the following maternal, neonatal, and long- term offspring outcomes? | Question A: Is this research question clearly worded? | No. See previous questions. Also, administration route is important and should be included--so, short-acting but also subcutaneous insulin infusions in addition to type of insulin. Additionally, glycemic control might not be measured by the measures you mention — what about fructosamine or glycated albumin? Fasting and 2- hour glucose values fluctuate so much day to day and that is the reason that HgbA1c is recommended for testing postpartum now, although HgbA1c is obviously not ideal in pregnancy due to its long half- life. | Yes | No. The question is unclear as far as what you are comparing. Are you comparing single long or intermediate acting insulin injection given at a regular interval to a long acting insulin supplemented with short acting insulin titrated by blood sugar? | Yes | Yes | Yes | No. Same as 1-1 for issues of efficacy and outcome specification. Not clear what ‘other insulin regimens’ would include. Research question should be more specific in defining comparison group. | No. Similar to previous questions. Very important to add postpartum weight retention. Reword pregnancy weight gain and use “gestational weight gain”. The weight gain before and after treatment should be separately evaluated. Glycemic control may involve 1 hr or 2 hr postprandial data. | No. “What are the safety and effectiveness...”. same comments about neonatal outcomes. All the different examples are confusing. Could this be simplified “What are the comparative effectiveness and safety of various individual insulin regimens...”? | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 6 | 4 | 6 | 6 | 8 | 8 | 7 | 5 | 8 | 6.4 | 5 | 8
| | Question C: Rationale for above rating | Administration methods are likely to be studied in near future. | I am not sure “one size” will fit all. | Really unsure of the question, however this could be very important if it is identifying the most effective insulin dosing regimen. | While of great interest, the issues of the best insulin regimen are a little less pressing than the use of oral agents. We do need to know whether and to what extent some of the newer insulin analogs cross the placenta and whether that might have an effect on the offspring. | It would be useful to compare different insulin regimens during pregnancy. Most studies have been in nonpregnant patients. | - | - | Much more data exist regarding the safety and efficacy of insulin treatment for GDM. The specific regimens are adapted for individual glucose control. | - | N/A | N/A | N/A
I-4 | What is the effectiveness and safety of other hypoglycemic drug classes (e.g. thiazolidinediones, DPP-4 inhibitors, GLP1 agonists, meglitinides) compared to any insulin in the treatment of gestational diabetes with regard to the following maternal, neonatal, and long- term offspring outcomes? | Question A: Is this research question clearly worded? | No. I am not sure that lumping these drugs into a single category is that useful? Do you want to consider each separately? | Yes | Yes | Yes | Yes | Yes | No. Will any insulin treatment be too heterogeneous to provide any useful information? Given the differences in both groups this comparison will be difficult to sort out. | No. Same comments related to outcomes statements. | No. Same comments as for question I-1. | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 5 | 3 | 8 | 7 | 7 | 8 | 5 | 4 | 5 | 5.8 | 3 | 8
| | Question C: Rationale for above rating | - | I am not sure we should more forward with other agents until the issue has been resolved with the two most commonly used. | - | If any of these agents are safe and effective in pregnancy it would be terrific. However, currently there is very little information on the most basic of issues - do they cross the placenta at various times in gestation? Before trials in human are undertaken I believe animal models should be investigated. The action of many of these drugs is very complex and fetal effects would be quite unpredictable without animal models first. | - | - | - | These questions are beneficial only if other oral medications that have been widely used in humans for diabetes management and have limited transport across the placenta do not demonstrate efficacy and safety. | Given the warnings associated with some of these newer classes, it seems less likely that they’ll be embraced for use in pregnancy. | N/A | N/A | N/A
I-Study Needs/Challenges | Populations; - Racial distribution of study participants; Study Designs; - RCTs; - Observational (population-based) studies to observe patterns of drug utilization and its effect on maternal and fetal outcomes; Analyses; - Intention-to-treat analyses; - Specific analyses by race, socioeconomic status, education level, and access-to- care (e.g. insurance status, language, transportation); Outcomes; - Consistent ascertainment, definition, and measurement of outcomes (across studies); Short-Term – Neonatal and maternal hypoglycemia, birth trauma, perineal tears, postpartum hemorrhage, etc.; Long-Term –Infantile growth trajectory, neonatal & maternal metabolic alterations & adiposity, etc.; Other Issues; - Optimal glucose thresholds for initiating therapy?; - Consistent reporting of baseline glucose tolerance levels | - | - | We need to standardize how we diagnose GDM. | In analyses, add in previous GDM and family history of diabetes. | Pharmacologic, pharmacokinetic studies, animal models to look at potential fetal effects and long-term offspring effects are of great importance here. Furthermore, many of the outcomes of interest are rare and would require large sample sizes (shoulder dystocia, for example). Long-term followup studies are expensive and labor intensive. Long-term studies must include more than the neonatal and early childhood periods. Older studies on obesity show that macrosomic offspring experience “catch- down” growth in the first few years, only to re-emerge as obese in late childhood and early teens. | - | Should development of type 2 diabetes mellitus in the mother postpartum be added as a long-term outcome? | Sample size, especially for subgroup comparisons. Not clear if neonatal development should be measured as well. Consistency of timing of followup postpartum for maternal and neonatal measures. Within treatment type heterogeneity. Inclusion of lifestyle interventions as a confounder. | Postpartum weight retention in women, and gestational weight gain after GDM diagnosis and treatment initiated. | Measuring adherence. The question of optimal glucose thresholds for initiating therapy could stand alone as a research question. | N/A | N/A | N/A
II-1 | What is the effectiveness and safety of elective labor induction at 40 weeks compared to expectant management in women with gestational diabetes* with regard to the following maternal and neonatal outcomes?*Populations of Interest:; - All women with gestational diabetes; - Women with insulin-requiring (class A2) gestational diabetes; - Obese women with gestational diabetes; - Women with gestational diabetes with high estimated fetal weight (e.g. > 4000 or > 4500 grams); - Women with different parities; - Women of various races/ethnicities | Question A: Is this research question clearly worded? | Yes | Yes | No. Again, reword outcomes to make them more patient centered. Actual question is fine. | Yes | Yes | Yes | Yes | No. Women treated with oral agents. | No. “What are the effectiveness and safety...”. Same comments about neonatal outcomes. Is elective induction at 39 weeks specifically excluded from research interest? Why? | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 7 | 8 | 8 | 9 | 8 | 6 | 8 | 7 | 7.8 | 6 | 9
| | Question C: Rationale for above rating | Consider cost- effectiveness as well as effectiveness. | - | Need to know the extent of influence mode and timing of delivery has on outcome. | This is a very pressing question. I would probably also select 39 weeks as a potential time for elective induction to be evaluated, since a number of epidemiologic studies have demonstrated significantly greater neonatal morbidity when elective induction of repeat cesarean section is performed before 39 weeks. | There is a paucity of evidence regarding this issue. In contrast, there is an abundance of opinion. | - | Definition of what cesarean section indication is critical. Consistency and complete measurement has been very problematic. | - | - | N/A | N/A | N/A
II-2 | What is the effectiveness and safety of elective cesarean delivery at 40 weeks compared to expectant management in women with gestational diabetes* with regard to the following maternal and neonatal outcomes?*Populations of Interest:; - All women with gestational diabetes; - Women with insulin-requiring (class A2) gestational diabetes; - Obese women with gestational diabetes; - Women with gestational diabetes with high estimated fetal weight (e.g. > 4000 or > 4500 grams); - Women with different parities; - Women of various races/ethnicities | Question A: Is this research question clearly worded? | No. As mentioned for previous section, consider cost- effectiveness as well as effective-ness. | Yes | Yes | Yes | Yes | Yes | No. Without clear specifications of what elective cesarean section is/is not, this isn’t clear. | Same comment as previous. | No. Same comments as for Question II-1. | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 7 | 8 | 4 | 9 | 8 | 7 | 7 | 7 | 7.3 | 4 | 9
| | Question C: Rationale for above rating | - | - | Same as previous question. | With the exception of the need to have an appropriate definition of macrosomia to trigger cesarean section without labor, I don’t think this is a very compelling question. I believe that randomized trials would be necessary to answer the question, and randomization to elective cesarean section in patients whose EFW is not large would be very problematic. | See prior comment. | - | - | - | - | N/A | N/A | N/A
II-Study Needs/Challenges | Study Designs; - Observational studies with adjustment for factors that affect labor management (e.g. SES); - RCTs/observational studies to address cesarean delivery based on EFW or gestational age Analyses; - Stratified analyses (if diet-controlled and insulin- controlled women with gestational diabetes are included); - Stratified analyses by race/ethnicity; - Stratified analyses by prior delivery history | - | - | What about stratification by glucose control? | Also stratify by previous GDM. | - | - | - | Measurement of indication for cesarean section is a major challenge. Stratif by oral agent subgroups with GDM. | Stratify by oral agent subgroups with GDM. | - | N/A | N/A | N/A
III-1 | What is the evidence that maternal health behaviors (e.g. breastfeeding, physical activity, diet) are associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | Physical activity and diet during pregnancy vs. after pregnancy, or no distinction? | Yes | Yes | Yes | Yes | Yes | Yes | No. Lactation duration and intensity. | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 9 | 9 | 8 | 8 | 7 | 7 | 9 | 7 | 8.1 | 7 | 9
| | Question C: Rationale for above rating | - | With the epidemic of diabetes we are facing, prevention is critical. | Resulting information will help target women who require close observation postpartum. | We are experiencing an epidemic of type 2 diabetes and if we can better predict who will get it we may be better able to intervene. | - | - | - | Only one study examined the risk of type 2 diabetes mellitus among women with a history of GDM, and the study found no association in the retrospective analysis of white women. This study relied on self-report of type 2 diabetes mellitus, and did not obtain and biochemical measurements of glycemia before or after lactation. | - | N/A | N/A | N/A
III-2 | What is the evidence that maternal psychosocial factors (e.g. mood disorders, eating disorders, stress) are associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | No. Would you also add in issues such as domestic violence and substance use disorders? | Yes | Yes | No. Should stress be defined as psychosocial stress? I assume you aren’t referring to stress associated with heavy physical work. | No. Substance use disorders (not clear what is included in mood disorders). | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 7 | 8 | 5 | 4 | 6 | 6 | 4 | 5 | 6.0 | 4 | 9
| | Question C: Rationale for above rating | Very important and totally understudied. | - | Again, information helps to both target women at high risk and provide medical rationale for addressing situations that are otherwise overlooked as not the role of the medical provider. | I’d include with previous research question. | - | - | - | These factors are likely mediated by weight gain and changes in lifestyle behaviors that have adverse effects on glucose tolerance. | - | N/A | N/A | N/A
III-3 | What is the evidence that maternal metabolic measures (e.g. fasting insulin levels, OGTT measures, HPA axis stress (subclinical hypercortisolism)) are associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | No. These are very broad categories. Consider subcategorizing maternal metabolic measures into more specific categories, such as adipocytokines; stress, and perhaps listing other categories- chemokines, vitamin D, etc. | Yes | Yes | Yes | Yes | Yes | No. Not clear if metabolic measures are during pregnancy or postpartum. | - | - | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 7 | 9 | 5 | 7 | 6 | 5 | 3 | 8 | 6.6 | 3 | 9
| | Question C: Rationale for above rating | Risk stratification markers are needed. | Knowledge of risk factors will hopefully identify potential strategies for prevention. | Would it also be important to add in the timing of those measures: 6 weeks postpartum, 6 months postpartum?? | Include with previous two question. | - | - | - | Many studies have already been published which demonstrate that these risk factors predict type 2 diabetes mellitus after GDM pregnancy. | - | N/A | N/A | N/A
III-4 | What is the evidence that pre-pregnancy, antenatal, and postpartum co- morbid conditions (e.g. obesity, hypertension, hypercholesterolemia) are associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | No. Consider listing pre- conception biomarkers, such as the ones listed in the previous question. | Yes | Yes | Yes | Yes | Yes | No. Need to clarify what conditions are prepregnancy, pregnancy induced, and when they are measured postpartum. Without these clarifications there is too much ambiguity. | No. Pre- pregnancy cardiometabolic risk factors (atherogenic lipid profiles, pre- diabetes, abdominal obesity). | - | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 7 | 8 | 5 | 9 | 6 | 5 | 9 | 8 | 7.3 | 5 | 9
| | Question C: Rationale for above rating | Monique Hedderson has had an R01 (score 8th percentile) which is examining pre- pregnancy factors for prediction of GDM. I am not sure if powered or funded for longer followup postpartum. | As with previous questions... | - | These are all variables that could be included in the first question in this series. All are important to study. | - | - | This is somewhat messy given pre, ante, and postnatal are all included at once. It will be difficult to determine what the critical period is. If it is pregnancy induced (hypertension) or not will be important to differentiate. The question is important/interesting, just ambiguous. | Pre-pregnancy metabolic risk factors should be identified to screen and identify women during the interconceptual period who are at risk for GDM in a future pregnancy. Atherogenic lipid profiles include low HDL and elevated triglycerides and not simply hyper-cholesterolemia. | - | N/A | N/A | N/A
III-5 | What is the evidence that contraceptive method (e.g. depo- provera) is associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | No. Add in hormonal contraceptive method used within x months of pregnancy. Women often use multiple methods, especially those who become pregnant. | Yes | Yes | Yes | No. What kind of contraceptive method? Is the question addressing classes of contraceptives ? This question lacks specificity. | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 3 | 7 | 3 | 9 | 3 | 5 | 6 | 2 | 6 | 4.9 | 2 | 9
| | Question C: Rationale for above rating | Studied in small populations already. | - | Interesting question, however the timing of the contraceptive method to the pregnancy and the consistency of use of one method would make this a difficult research question. | We desperately need more information about appropriate contraception for former GDMs … all future pregnancies should be planned pregnancies for them. | - | - | - | The glucose intolerance associated with these methods is well-known, and not recommended in women with previous GDM. | - | N/A | N/A | N/A
III-6 | What is the evidence that the inter- conception interval is associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | Yes | No. Please identify factors under consideration, i.e. weight gain, behaviors, physical activity. Is that what was intended by the question? | No. Add an amount of time such as under 12 months after inter- conception interval and compare that to women with an inter- conception interval over 12 months. | Yes | Yes | Yes | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 5 | 7 | 7 | 5 | 7 | 5 | 4 | 5 | 5 | 5.6 | 4 | 7
| | Question C: Rationale for above rating | This is interesting although it might be very difficult to study since interval between pregnancies confounded by other factors (access to contraception; socio- economic status, etc.). | - | - | Interesting question, just not as high priority for me as some of the previous ones, since decisions about family planning are tough to influence even if we know the answer. | I’m uncertain whether this has been studied before but it is an interesting question. | - | It is unclear if the first or second pregnancy is the GDM index pregnancy. The potential for changing pregnancy interval as an intervention is rather distal and there are likely more effective interventions that address other factors. | Somewhat important but primarily related to postpartum weight retention. | - | N/A | N/A | N/A
III-7 | What is the evidence that family history, gene mutations, genotypes, gene- environment interactions, epigenetic modifications, or other biomarkers are associated with the risk of developing type 2 diabetes among women with gestational diabetes? Are there differences in these associations by race or ethnic group? | Question A: Is this research question clearly worded? | No. Very broad-consider subdividing into sub- categories. | Yes | Yes | Yes | Yes | Yes | No. How is this going to be measured? This covers just about everything one might think of as far as genetics goes. It would be better to focus on a subset of the list where there could be some possibility of useful interventions being developed. | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 9 | 9 | 8 | 9 | 5 | 3 | 7 | 8 | 7.4 | 3 | 9
| | Question C: Rationale for above rating | - | - | Data to identify at risk women and target resources. | These are critical questions in dealing with the epidemic of type 2 diabetes. | A straight-forward and objective study. | - | The question as written will not provide an evidence base that can be used. Because the question is so broad nothing can be done with the findings — lack of comparability. | Specific genetic markers among women with GDM are not well characterized. | - | N/A | N/A | N/A
III-8 | What is the comparative effectiveness of various lifestyle interventions for prevention of type 2 diabetes mellitus, glucose intolerance, and obesity in women with a history of gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | No. Define lifestyle interventions. | Yes | Yes | No. Some examples of lifestyle interventions would be helpful, i.e., diet, physical activity, smoking. | No. Without some clear definition of lifestyle interventions findings from such studies will not be useful to the larger population. | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 9 | 8 | 6 | 8 | 7 | 6 | 8 | 8 | 7.7 | 6 | 9
| | Question C: Rationale for above rating | Not much out there! It might be hard to compare comparative effectiveness. This kind of info is limited for lifestyle interventions outside of pregnancy-- but could consider value of face-to-face vs. internet vs. telephone, etc. I think Cochrane has done something like this, at least for diabetes treatment or weight management. | Prevention is critical. | Strong evidence of lifestyle intervention as a preventive measure for diabetes may improve resources for promotion. | The results of the large NIH sponsored study on prevention of type 2 diabetes shed some light on this, but further data specific to women with history of GDM would be helpful. | Very important for prevention. | - | Comparative effectiveness research should include lifestyle and pharmacological interventions. Not clear why this is limited to just lifestyle. | Few RCTs have been conducted in this population to assess appropriate timing for the intervention. | - | N/A | N/A | N/A
III-9 | What is the comparative effectiveness of various innovative strategies and technologies to disseminate educational materials on prevention of type 2 diabetes mellitus and glucose intolerance to women with a history of gestational diabetes?” | Question A: Is this research question clearly worded? | Yes | Yes | Yes | Yes | Yes | No. Some examples of innovative strategies and technologies would be helpful. | No. Various innovative strategies is too vague. | Yes | No. Remove the word ‘innovative’, as one wouldn’t want to exclude the possibility that a non-innovative (low cost, sustainable) strategy could favorably compare to an innovative (high cost, nonsustainable) strategy. Any strategy should be eligible for testing. | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 1 | 9 | 9 | 8 | 5 | 6 | 6 | 8 | 7 | 6.6 | 1 | 9
| | Question C: Rationale for above rating | Doesn’t really matter how you disseminate materials if they don’t work. It has been shown that knowledge is not the primary barrier. | - | Wonderful. These women are consumers at this point, not patients and make their own choices based on identified needs. Reaching them with clear compelling messages that trigger action is key. | Obviously if successful strategies can be found it would be very helpful. | - | - | Definition of strategies is too vague for multiple researchers to take this question on and have an impact on the body of evidence. This is a high risk population so it has the potential to be important. | - | - | N/A | N/A | N/A
III-Study Needs/Challenges | Populations; - Consistency in race/ethnicity (across studies); - Need for recruitment at time of gestational diabetes diagnosisStudy Designs; - Observational studies with ascertainment of covariates and confounders; - Random or purposeful sampling for more representative samples; Analyses; - Multivariate analyses for pooled estimates of risk; Other Issues; - Consistency in risk factors and their definitions (across studies); - Focus on specific categories of anthropometry (e.g. BMI, weight) and reproductive factors (e.g. parity) | - | - | As before, consistency in diagnosis. | - | RCTs would be helpful and important in evaluating prevention strategies. | - | Under other issues, one should also consider age (i.e., the older pregnant woman). | Timing of measurement for factors (prepregnancy, during or postpartum, and then when post partum). Definition of interventions being compared and if they are evidence based or not. | Lactation support needs to be evaluated in the intervention trials, and when to intervene during the postpartum period. | - | N/A | N/A | N/A
IV-1 | What are the performance characteristics (sensitivity, specificity, and reproducibility) of a single fasting blood glucose test compared to the full 2-hour 75-gm OGTT in screening for type 2 diabetes following a pregnancy with gestational diabetes? Does the accuracy of the fasting blood glucose test compared to the full 2-hour 75-gm OGTT vary with the postpartum testing interval in screening for type 2 diabetes following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | No.Already studied--as long as OGTT is considered as gold standard, FBG will always perform more poorly than OGTT. To resolve this question, we need to have long-term data on complications. | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 1 | 9 | 9 | 4 | 8 | 7 | 6 | 4 | 5 | 5.9 | 1 | 9
| | Question C: Rationale | Should consider HgbA1c as well, since ADA has recommended that as a screening test. | Women are not receiving their postpartum followup. Need to explore similar means of diagnosis to increase compliance. | Extremely important. Difficult to capture women postpartum for testing, particularly a 2 hour OGTT however women are more amenable to a quick fasting blood sugar. Learning something about the correlation could be critical. | Given the recent ADA recommendations for HgbA1c to diagnose diabetes mellitus (but not so good for prediabetes), and the already demonstrated inadequacy of fasting glucose determinations to find cases of impaired glucose tolerance, and the importance of diagnosing prediabetes in these women who are “at risk” for another pregnancy in the near future, I believe that this issue is not at the top of the list. If it is to be done, HgbA1c levels should also be evaluated for their efficiency at diagnosis. | - | - | - | Evidence shows that a high proportion of women with glucose intolerance after GDM are missed if fasting only is used. | Research on the testing interval seems more important than research comparing tests. | N/A | N/A | N/A
IV-2 | What are the performance characteristics (sensitivity, specificity, and reproducibility) of the HgBA1c test compared to the 2- hour 75-gm OGTT in screening for type 2 diabetes following a pregnancy with gestational diabetes? | Question A: Is this research question clearly worded? | No. I see you already thought of this! While less studied, similar limitations- HgbA1c will do more poorly. But I think it is important. | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No. Add testing interval component. | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 9 | 9 | 5 | 8 | 7 | 5 | 9 | 5 | 7.3 | 5 | 9
| | Question C: Rationale for above rating | See above and previous comment. | As with previous question.... | The necessary timing of the HgbA1c at over 4 months postpartum makes it close to impossible for women without private insurance to be tested as state Medicaid runs out 90 days postpartum. The 2 hr OGTT can be preformed at 6 weeks postpartum. | By current standards, neither HgbA1c nor the 75 gram OGTT are screening tests...they are diagnostic tests. Again, I believe that the diagnosis of prediabetes is particularly important for this group of subjects. | Might make diagnosis easier. | - | - | HgbA1c test compared with the 2 hr OGTT is an extremely important comparison. | - | N/A | N/A | N/A
IV-3 | What is the comparative effectiveness of various strategies or interventions to improve clinician compliance with postpartum screening guidelines for type 2 diabetes mellitus and glucose intolerance in women with a history of gestational diabetes? | Question A: Is this research question clearly worded? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 9 | 9 | 9 | 7 | 5 | 7 | 8 | 9 | 7 | 7.8 | 5 | 9
| | Question C: Rationale for above rating | Definitely needed. Might help if you give some examples-- automated reminders, mailings, patient case- management, etc. | Sound strategies are needed on both sides. | - | This process is tedious and long since we can’t stop and then resume at a later time. I am getting grouchy and thus less likely to describe my rationale. There must be a way to enhance the program so we can partially complete the task and then go back to it. | The strategies would need to be very specific. | - | This is a practice pattern that has the potential to improve the health of women and is inconsistently done. Getting this done and implementing appropriate interventions has the potential to improve health. | - | - | N/A | N/A | N/A
IV-4 | What is the comparative effectiveness of various innovative strategies or technologies (e.g. electronic health records) to track postpartum screening for the development of type 2 diabetes mellitus and glucose intolerance in women with a history of gestational diabetes? | Question A: Is this research question clearly worded? | No. Anything else besides electronic health records? Need something to compare them to. | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | N/A | N/A | N/A
| | Question B: Likely clinical benefit? (scale=1 to 9) | 5 | 7 | 9 | 4 | 4 | 7 | 8 | 9 | 6 | 6.6 | 4 | 9
| | Question C: Rationale for above rating | - | - | - | - | - | - | - | Kaiser Permanente has already implemented the electronic medical record nationwide which tracks laboratory screening tests of members. | - | N/A | N/A | N/A
IV-Study Needs/Challenges | Populations; - Consistency in terms of race/ethnicity and future diabetes risk (family history of type 2 diabetes, prior gestational diabetes, etc.) (across studies); - Consistent protocols for recruitment of participants (across studies); Other Issues; - Do the screening test and interval of followup vary based on maternal risk factors other than gestational diabetes? | - | - | - | Add in insurance factors and family stability - a new baby may mean moving and poor means of followup. | - | - | - | Timing of first screen postpartum. | - | - | N/A | N/A | N/A
Additional | - | Do you have any general comments? | Very nice formulation of issues! Comments were minor editorial. Consider placental factors, inclusion of lipids particularly free fatty acids. | - | Thanks for involving me in the survey. | Too long to do all in one session. My later answers are undoubtedly less thoughtful than earlier ones. | - | - | - | - | Well done! Thanks very much for asking me to participate. | N/A | N/A | N/A

Abbreviations: ADA=American Diabetes Association, FBG=fasting blood glucose, GDM=gestational diabetes mellitus, HDL=high density lipoprotein, OGTT=oral glucose tolerance test, RCT=randomized controlled trial.