# Results from Step 5 (Online Feedback, Consensus Development, and Prioritization of Research Questions by External Stakeholders (Delphi Approach))

Key Question Number | Key Question Topic | Research Question Number | Research Question (as entered into Delphi Round 1)^*^ | Clinical Benefit/Importance (Mean, Range on a Scale of 1-9) Delphi Round 1 | Clinical Benefit/Importance (Mean, Range on a Scale of 1-9) Delphi Round 2 | Clinical Benefit/Importance (Mean, Range on a Scale of 1-9) Delphi Round 3 | Included in Final List of Research Questions of High Clinical Benefit/Importance?
I | Benefits and harms of oral diabetes agents as compared to all types of insulin | I-1 | What is the effectiveness and safety of any of the second generation sulfonylureas compared to any insulin in the treatment of gestational diabetes with regard to the following maternal, neonatal, and long- term offspring outcomes?^**^ | Mean=8.2 Range=7 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | N/A^****^ | √
I | Benefits and harms of oral diabetes agents as compared to all types of insulin | I-2 | What is the effectiveness and safety of metformin compared to any insulin in the treatment of gestational diabetes with regard to the following maternal, neonatal, and long-term offspring outcomes?^**^ | Mean=7.9 Range=6 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | N/A^****^ | √
I | Benefits and harms of oral diabetes agents as compared to all types of insulin | I-3 | What is the effectiveness and safety of individual insulin regimens (e.g., long or intermediate acting) or combination regimens (e.g., long + short-acting) compared to other insulin regimens or combination regimens in the treatment of gestational diabetes with regard to the following maternal, neonatal, and long- term offspring outcomes?^**^ | Mean=6.4 Range=4 to 8 (No Consensus) | Mean=7.3 Range=6 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | √
I | Benefits and harms of oral diabetes agents as compared to all types of insulin | I-4 | What is the effectiveness and safety of other hypoglycemic drug classes (e.g., thiazolidinediones, DPP-4 inhibitors, GLP-1 agonists, meglitinides) compared to any insulin in the treatment of gestational diabetes with regard to the following maternal, neonatal, and long-term offspring outcomes?^**^ | Mean=5.8 Range=3 to 8 (No Consensus) | Mean=6.7 Range=3 to 9 (No Consensus) | Mean=6.9 Range=4 to 9 (Consensus - HIGH IMPORTANCE) | √
II | Benefits and harms of elective cesarean delivery or the choice of timing of induction | II-1 | What is the effectiveness and safety of elective labor induction at 40 weeks compared to expectant management in women with gestational diabetes with regard to the following maternal and neonatal outcomes?^***^ [underlined: Populations of Interest:]; - All women with gestational diabetes; - Women with insulin-requiring (class A2) gestational diabetes; - Obese women with gestational diabetes; - Women with gestational diabetes with high estimated fetal weight (e.g., >4000 or >4500 gram); - Women with different parities; - Women of various races/ethnicities | Mean=7.8 Range=6 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | N/A^****^ | √
II | Benefits and harms of elective cesarean delivery or the choice of timing of induction | II-2 | What is the effectiveness and safety of elective cesarean delivery at 40 weeks compared to expectant management in women with gestational diabetes^*^ with regard to the following maternal and neonatal outcomes?^***^ [underlined: Populations of Interest:]; - All women with gestational diabetes; - Women with insulin-requiring (class A2) gestational diabetes; - Obese women with gestational diabetes; - Women with gestational diabetes with high estimated fetal weight (e.g., >4000 or >4500 gram); - Women with different parities; - Women of various races/ethnicities | Mean=7.3 Range=4 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | N/A^****^ | √
III | Risk factors associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes | III-1 | What is the evidence that maternal health behaviors (e.g., breastfeeding, physical activity, diet) are associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Mean=8.1 Range=7 to 9(Consensus - HIGH IMPORTANCE) | N/A^****^ | N/A^****^ | √
III | Risk factors associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes | III-2 | What is the evidence that maternal psychosocial factors (e.g., mood disorders, eating disorders, stress) are associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Mean=6.0 Range=4 to 9 (No Consensus) | Mean=6.0 Range=4 to 8 (No Consensus) | Mean=6.0 Range=5 to 8 (No Consensus)
III | Risk factors associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes | III-3 | What is the evidence that maternal metabolic measures (e.g., fasting insulin levels, OGTT measures, HPA axis stress (subclinical hypercortisolism)) are associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Mean=6.6 Range=3 to 9 (No Consensus) | Mean=7.3 Range=6 to 8 (Consensus - HIGH IMPORTANCE) | N/A^****^ | √
III | Risk factors associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes | III-4 | What is the evidence that pre- pregnancy, antenatal, and postpartum co-morbid conditions (e.g., obesity, hypertension, hypercholesterolemia) are associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Mean=7.3 Range=5 to 9 (No Consensus) | Mean=7.4 Range=6 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | √
III | Risk factors associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes | III-5 | What is the evidence that contraceptive method (e.g., depo-provera) is associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Mean=4.9 Range=2 to 9 (No Consensus) | Mean=5.7 Range=3 to 8 (No Consensus) | Mean=5.9 Range=4 to 8 (No Consensus)
III | Risk factors associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes | III-6 | What is the evidence that the inter-conception interval is associated with the risk of developing type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | Mean=5.6 Range= 4 to 7(No Consensus) | Mean=5.3 Range=2 to 8(Consensus - MEDIUM IMPORTANCE) | N/A^****^
III | Risk factors associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes | III-7 | What is the evidence that family history, gene mutations, genotypes, gene-environment interactions, epigenetic modifications, or other biomarkers are associated with the risk of developing type 2 diabetes among women with gestational diabetes? Are there differences in these associations by race or ethnic group? | Mean=7.4 Range=3 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | N/A^****^ | √
III | Risk factors associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes | III-8 | What is the comparative effectiveness of various lifestyle interventions for prevention of type 2 diabetes mellitus, glucose intolerance, and obesity in women with a history of gestational diabetes? | Mean=7.7 Range=6 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | N/A^****^ | √
III | Risk factors associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes | III-9 | What is the comparative effectiveness of various innovative strategies and technologies to disseminate educational materials on prevention of type 2 diabetes mellitus and glucose intolerance to women with a history of gestational diabetes? | Mean=6.6 Range=1 to 9 (No Consensus) | Mean=7.3 Range=2 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | √
IV | Performance characteristics (sensitivity, specificity, and reproducibility) of tests for diagnosing type 2 diabetes following a pregnancy with gestational diabetes | IV-1 | What are the performance characteristics (sensitivity, specificity, and reproducibility) of a single fasting blood glucose test compared to the full 2-hour 75-gm OGTT in screening for type 2 diabetes following a pregnancy with gestational diabetes? Does the accuracy of the fasting blood glucose test compared to the full 2-hour 75-gm OGTT vary with the postpartum testing interval in screening for type 2 diabetes following a pregnancy with gestational diabetes? | Mean=5.9 Range=1 to 9 (No Consensus) | Mean=6.6 Range=4 to 9 (No Consensus) | Mean=6.7 Range=1 to 9 (Consensus - HIGH IMPORTANCE) | √
IV | Performance characteristics (sensitivity, specificity, and reproducibility) of tests for diagnosing type 2 diabetes following a pregnancy with gestational diabetes | IV-2 | What are the performance characteristics (sensitivity, specificity, and reproducibility) of the HbA1c test compared to the 2-hour 75-gm OGTT in screening for type 2 diabetes following a pregnancy with gestational diabetes? | Mean=7.3 Range=5 to 9 (No Consensus) | Mean=7.9 Range=6 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | √
IV | Performance characteristics (sensitivity, specificity, and reproducibility) of tests for diagnosing type 2 diabetes following a pregnancy with gestational diabetes | IV-3 | What is the comparative effectiveness of various strategies or interventions to improve clinician compliance with postpartum screening guidelines for type 2 diabetes mellitus and glucose intolerance in women with a history of gestational diabetes? | Mean=7.8 Range=5 to 9 (Consensus - HIGH IMPORTANCE) | N/A^****^ | N/A^****^ | √
IV | Performance characteristics (sensitivity, specificity, and reproducibility) of tests for diagnosing type 2 diabetes following a pregnancy with gestational diabetes | IV-4 | What is the comparative effectiveness of various innovative strategies or technologies (e.g., electronic health records) to track postpartum screening for the development of type 2 diabetes mellitus and glucose intolerance in women with a history of gestational diabetes? | Mean=6.6 Range=4 to 9 (No Consensus) | Mean=6.2 Range=2 to 9 (No Consensus) | Mean=5.8 Range=3 to 8 (No Consensus)

* The wording of research questions and outcomes in this table and footnotes reflects the wording of research questions and outcomes as entered into Delphi round 1. The wording of some research questions and outcomes was modified as appropriate during Delphi rounds 1, 2, and/or 3 on the basis of feedback from the external stakeholders. The final wording of highly important research questions is provided in Table 6. The final wording of research questions that did not make the final list of highly important research questions is provided in Table 3.

** Outcomes for Research Questions I-1, I-2, I-3, and I-4

Maternal Outcomes: mortality, cesarean delivery (including primary cesarean and repeat cesarean), indication for cesarean delivery, complications of cesarean delivery (e.g., wound infection, wound dehiscence), vaginal delivery (and specify type: spontaneous or operative), perineal tears, hemorrhage, hypoglycemia, shoulder dystocia, pregnancy weight gain, glycemic control (e.g., fasting blood glucose, 2-hr postprandial glucose, development of postpartum type 2 diabetes mellitus, hypertensive disorders of pregnancy (e.g., gestational hypertension, preeclampsia), patient-reported outcomes (e.g., patient treatment preference, quality of life), and medication adherence

Neonatal Outcomes: mortality, anoxia, birth trauma (e.g., bone fractures, brachial plexus palsy), birth weight, hyperbilirubinemia, hypoglycemia, large for gestational age and macrosomia, small for gestational age, macrosomia, neonatal intensive care admission, and respiratory distress syndrome

Long-Term Offspring Outcomes: growth, anthropometrics, and chronic diseases (e.g., obesity, diabetes).

*** Outcomes for Research Questions II-1 and II-2

Maternal Outcomes: mortality, cesarean delivery (including primary cesarean and repeat cesarean), indication for cesarean delivery, complications of cesarean delivery (e.g., wound infection, wound dehiscence), vaginal delivery (spontaneous, operative), perineal tears, hemorrhage, patient-reported outcomes (e.g., patient preference, quality of life), adherence, length of hospital stay, and pulmonary embolism

Neonatal Outcomes: mortality, anoxia, birth trauma (e.g., bone fractures, brachial plexus palsy), birth weight, hyperbilirubinemia, hypoglycemia, large for gestational age and macrosomia, small for gestational age, neonatal intensive care admission, and respiratory distress syndrome.

**** N/A=Not applicable. Consensus was already achieved in a previous Delphi round.

Abbreviations: DPP-4=dipeptidyl peptidase-4, GLP-1=glucagon-like peptide-1, HbA1c=hemoglobin A1c, HPA=hypothalamo-pituitary-adrenal, OGTT=oral glucose tolerance test.