# Results from Step 3 (Translation of Research Gaps into Researchable Questions) and Step 4 (Online and In-Person Feedback on Research Questions from Local Stakeholders)

Research Question Number | Initial Research Questions (As provided to local stakeholders for Online Feedback, Unless otherwise specified)^*^ | Comments from Online Feedback | Online Feedback—Likely Clinical Benefit/Importance Mean (Range) on a scale of 1–9 | Online Feedback—Likely Ability to Conduct a Study Mean (Range) on a scale of 1–9 | Comments from In-Person Meeting
I-1 | What is the comparative effectiveness and safety of any second generation sulfonylurea compared to any insulin in the treatment of gestational diabetes with regard to the following maternal and neonatal outcomes? [underlined: Maternal Outcomes:] weight, glycemic control, hypoglycemia, preeclampsia, operative vaginal delivery, hemorrhage, perineal tears, and cesarean delivery [underlined: Neonatal Outcomes:] birth trauma, anoxia, respiratory distress syndrome, birth weight, large for gestational age, macrosomia, small for gestational age, congenital malformations, hyperbilirubinemia, hypoglycemia, NICU admissions, and perinatal mortality | - It is unclear if it intends to evaluate the sulfonlyureas as a class or any specific sulfonylurea.; - Rewording suggested to include the following: “How does the effectiveness and safety profile of a ... compare to(with) that of ... in the treatment of ...?” | 7.8 (7–9) | 6.3 (3–9) | -
I-2 | What is the comparative effectiveness and safety of metformin compared to any insulin in the treatment of gestational diabetes with regard to the following maternal and neonatal outcomes? [underlined: Maternal Outcomes]: weight, glycemic control, preeclampsia, hemorrhage, operative vaginal delivery, perineal tears, and cesarean delivery [underlined: Neonatal Outcomes]: birth trauma, anoxia, respiratory distress syndrome, birth weight, large for gestational age, macrosomia, small for gestational age, congenital malformations, hyperbilirubinemia, hypoglycemia, NICU admissions, and perinatal mortality | - Rewording suggested to include the following: “How does the effectiveness and safety profile of compare… to (with) that of …in the treatment of…?” | 7.8 (7–9) | 6.7 (5–8) | -
I-3 | What is the comparative effectiveness and safety of any oral hypoglycemic medication (i.e., a second generation sulfonylurea or metformin) compared with any insulin in the treatment of gestational diabetes with regard to the following maternal and neonatal outcomes? [underlined: Maternal Outcomes]: cesarean delivery [underlined: Neonatal Outcomes]: birth trauma, fetal weight, and macrosomia | - Rewording suggested to include the following: “How does the effectiveness and safety profile of… compare to (with) that of ... in the treatment of ...?”; - Unclear as to why only looking at these limited outcomes in this case. | 7.3 (6–8) | 7.8 (7–9) | -
I-4 | What is the comparative effectiveness and safety of a short-acting vs. an intermediate or long-acting insulin in the treatment of gestational diabetes with regard to maternal and neonatal outcomes? | - It is unclear what these outcomes are.; - Could you also include rapid-acting insulin (along with short-acting)?; - Not clear if you really mean to compare these to each other or within each type of insulin.; - Previous questions delineated the maternal and neonatal outcomes of interest. It would be helpful to see specifically which of the outcomes may be impacted by these research questions.; - Need to clarify the outcomes. | 6.3 (3–8) | 5.5 (3–8) | - This question is not clinically relevant because short and intermediate insulin may be combined. Also regular insulin vs. insulin lispro would be a good comparison, but it is not related to key question I.
I-5 | What is the comparative effectiveness and safety of a short-acting insulin compared to diet alone in the treatment of gestational diabetes with regard to maternal and neonatal outcomes? | - Need to define the outcome of interest.; - Rewording suggested to include: “How does the effectiveness and safety of ... compare to (with) that of ...?”; - Need to clarify outcomes. | 6.7 (5–8) | 5 (3–8) | - If someone chooses diet alone they will not choose short-acting insulin.
I-6 | What is the comparative effectiveness and safety of oral hypoglycemic agents like thiazolidinediones (TZDs), exenetide, and sitagliptin in the treatment of gestational diabetes with regard to maternal and neonatal outcomes? | - Specify the nature of outcomes—short-term vs. long-term, surrogate outcomes vs. clinical outcomes vs. patient oriented outcomes.; - Not all these are considered “oral hypoglycemic agents.” Exenatide is an injectable non-insulin agent.; - Need to clarify outcomes. | 7.7 (7–9) | 5.2 (1–8) | - There are serious feasibility issues with using newer agents. Glyburide has been shown to not cross the placenta, thus it is acceptable to use in an RCT.; - In order to begin using newer agents there needs to be a build-up of their evidence base.
I-Outcomes of interest | [underlined: Maternal outcomes] cesarean delivery, glycemic control (FBG), 1-hr and 2-hr postprandial glucose (PPG), hemorrhage, hypoglycemia, operative vaginal delivery, perineal tears, preeclampsia, weight [underlined: Neonatal outcomes] anoxia, birth trauma, birth weight, congenital malformations, hyperbilirubinemia, hypoglycemia, large for gestational age, macrosomia, mortality, neonatal intensive care admissions, respiratory distress syndrome, shoulder dystocia, small for gestational age. ([underlined: Note]—These outcomes were not included in the online feedback process. They were discussed in the in-person meeting). | N/A | N/A | N/A | - Patient centered outcomes needed.; - Long-term offspring outcomes/developmental outcomes are needed.; - Shoulder dystocia is a maternal outcome.; - Shoulder dystocia is subjective.; - The outcomes collected across studies vary.; - Some outcomes should be split out.; - Operative vaginal delivery is subjective.; - Cesarean delivery should be changed to “cesarean delivery indication”.; - Should look at how many vaginal attempts resulted in cesarean deliveries and why cesarean deliveries were the chosen option (complications, etc.).; - In regards to glycemic control, should look at the difficulty in maintaining glycemic control (dosing).; - In regards to birth trauma, should also take into consideration bone fatigue specifications.
I-Study needs and challenges | [underlined: Populations]; - Racial distribution of study participants; [underlined: Study Designs]; - RCTs; [underlined: Analyses]; - Intention-to-treat analyses Race- specific analyses; [underlined: Other Issues]; - Optimal glucose thresholds for initiating therapy?; - Consistent reporting of baseline glucose tolerance levels; [underlined: Outcomes]; - Consistent ascertainment, definition, and measurement of outcomes (across studies); - Short-Term—Neonatal and maternal hypoglycemia, birth trauma, perineal tears, postpartum hemorrhage, etc.; - Long-Term—Infantile growth trajectory, neonatal & maternal metabolic alterations & adiposity, etc.; ([underlined: Note]— These study needs and challenges were not included in the online feedback process. They were discussed in the in-person meeting). | N/A ([underlined: Note]—These study needs and challenges were not included in the online feedback process. They were discussed in the in- person meeting). | N/A | N/A | - Additional suggestions included stratification by socio-economic status, education level, access to care, and screening.; - Explain trajectory of patients and possibly classify the severity of GDM through C-peptide levels, HbA1c, etc.
II-1 | What is the comparative effectiveness and safety of elective labor induction vs. expectant management at term in the management of labor in women with gestational diabetes with regard to the following maternal and neonatal outcomes? [underlined: Maternal Outcomes]: cesarean delivery, operative vaginal delivery, hemorrhage, perineal tears, and infection [underlined: Neonatal Outcomes]: birth trauma, anoxia, congenital malformations, hyperbilirubinemia, hypoglycemia, respiratory distress syndrome, shoulder dystocia, neonatal mortality, birth weight, large for gestational age, macrosomia, small for gestational age, and NICU admissions | - Rewording suggested to include the following: “In planning and managing delivery of women with gestational diabetes at term, how does the effectiveness and safety of elective labor induction compare to that of expectant management with regard to ...?” | 7.7 (7–8) | 5.3 (3–7) | - Should use ‘delivery’ vs. ‘labor’ in the wording of the question.; - Elective assumes that all other factors are OK, thus the following change should be made: “elective (with no complications)”.; - A previous cesarean delivery would exclude you from the study with the current practices. The term “at term” is vague. Should define by gestational age, term equals 40 weeks.
II-2 | What is the comparative effectiveness and safety of elective cesarean delivery vs. expectant management at term in the management of labor in women with gestational diabetes with regard to the following maternal and neonatal outcomes? [underlined: Maternal Outcomes]: hemorrhage and infection [underlined: Neonatal Outcomes]: birth trauma, anoxia, congenital malformations, hyperbilirubinemia, hypoglycemia, respiratory distress syndrome, shoulder dystocia, neonatal mortality, birth weight, large for gestational age, macrosomia, small for gestational age, and NICU admissions | - Rewording suggested to replace “management of labor” with “planning and management of delivery at term.”; - Suggest adding wound complications for maternal outcomes. Any interest in longer term outcomes (e.g., maternal incontinence, previa/acreta in future pregnancies, longer term baby outcomes like obesity, diabetes, cognitive function)? | 7.2 (6–8) | 5.8 (4–7) | - Stratify by EFW and by maternal weight.
II-3 | What is the comparative effectiveness and safety of elective labor induction or cesarean delivery compared to expectant management at term in the management of labor in women with insulin-requiring (class A2) gestational diabetes with regard to the following maternal and neonatal outcomes? [underlined: Maternal Outcome]: non-elective cesarean delivery (if elective induction is performed) [underlined: Neonatal Outcome]: macrosomia | - Using “comparative effectiveness” and “compared to” in same sentence is redundant and awkward; also suggest rewording to replace “management of labor” with “planning and management of delivery at term.”; - May want to look at more outcomes (especially neonatal). | 7.2 (6–8) | 6 (4–7) | N/A (This question was not discussed in the in-person meeting.)
II- Outcomes of interest (for II-1 & II-2 only) | [underlined: Maternal outcomes] cesarean delivery, operative vaginal delivery, hemorrhage, perineal tears, infection, non-elective cesarean delivery (if elective induction is performed) [underlined: Neonatal outcomes] anoxia, birth trauma, birth weight, congenital malformations, hyperbilirubinemia, hypoglycemia, large for gestational age, macrosomia, mortality, NICU admissions, respiratory distress syndrome, shoulder dystocia, small for gestational age ([underlined: Note]— These outcomes were not included in the online feedback process. They were discussed in the in-person meeting). | N/A | N/A | N/A | - Patient-centered outcomes needed.; - Long-term offspring outcomes/developmental outcomes are needed.; - Shoulder dystocia is a maternal outcome.; - Long-term studies collecting neonatal developmental outcomes are feasible.; - Shoulder dystocia is subjective.; - Some outcomes should be split out.; - Operative vaginal delivery is subjective.; - Cesarean delivery under the maternal outcomes heading should be changed to “indication for cesarean delivery.”; - Should look at how many vaginal attempts resulted in cesarean deliveries and why cesarean deliveries were the chosen option (complications, etc.).; - In regards to glycemic control, should look at the difficulty in maintaining glycemic control (dosing).; - In regards to birth trauma, should also take into consideration bone fatigue specifications.
II- Study needs and challenges (for II-1 & II-2 only) | [underlined: Study Designs]; - Observational studies with adjustment for factors that affect labor management (e.g., socio-economic status); - RCTs/observational studies to address cesarean delivery based on EFW or gestational age; [underlined: Analyses]; - Stratified analyses (if diet-controlled and insulin-controlled women with GDM are included); ([underlined: Note]—These study needs and challenges were not included in the online feedback process. They were discussed in the in-person meeting). | N/A ([underlined: Note]—These study needs and challenges were not included in the online feedback process. They were discussed in the in- person meeting). | N/A | N/A | - Will have problems with providers not following the random allocation.; - In larger populations crossing between arms is negligible.; - Can do cluster randomization.
III-1 | What is the evidence that presence of maternal lifestyle risk factors (e.g., behavioral risk factors, breastfeeding, physical activity, daily caloric intake) are associated with short-term and long-term development of type 2 diabetes mellitus or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | - Maybe focus on factors that accelerate progression to Type 2 diabetes mellitus, as women with GDM are already at risk.; - Suggest rewording to: “How strongly do specific elements of maternal lifestyle (...)correlate with short- and long-term development ...?” or “Following a pregnancy complicated by GDM, what is the impact of specific elements of maternal lifestyle (e.g., ...) on both short- and long-term development of ..?” | 8.2 (7–9) | 6.2 (4–7) | During the in-person meeting all research questions related to key question III were presented together. Thus comments were made on the questions as a whole, with specific questions being addressed when necessary. The comments were as follows:; - In addition to psychosocial factors should also look at anxiety disorders and eating disorders.; - Should also look at interpregnancy interval.; - Should look at the number of GDM- associated pregnancies of each person.; - Family history may be difficult to collect from individuals who do not know their family history.; - Should look at racial/ethnic groups.
III-2 | What is the evidence that presence of maternal psychosocial risk factors (e.g. depression, postpartum depression, other depressive postpartum mental health disorders, perceived stress, etc.) are associated with short-term and long-term development of type 2 diabetes mellitus or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | - Maybe add “accelerated progression” to short-term and long-term type 2 diabetes.; - See suggested wording for previous question... except that unlike in the other question which include examples of both positive and negative (or neutral) lifestyle elements and therefore are incorrectly being termed “risk factors,” here the examples are all risk factors. You could phrase the question as: “To what extent does the presence of maternal psychosocial risk factors increase the risk of developing ...?” | 7.5 (6–8) | 5.2 (5–6) | -
III-3 | What is the evidence that presence of maternal metabolic risk factors (e.g. insulin sensitivity, HPA axis stress (subclinical hypercortisolism)) are associated with short-term and long- term development of type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | - Maybe specify the timing of these risk factor assessments.; - Suggested rewording: “To what extent does the presence of maternal metabolic risk factors (e.g. ,...) increase the short- and long-term risk of developing ...?”; - Are the maternal risk factors present before, during, or after pregnancy? | 6.8 (5–9) | 5.2 (3–7) | -
III-4 | What is the evidence that presence of maternal co-morbidities (e.g., obesity, hypertension, hypercholesterolemia) are associated with short-term and long-term development of type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | - Specifiy whether maternal comorbidities are during pregnancy, before, or after. | 8 (7–9) | 7 (6–9) | -
III-5 | What is the evidence that progestin- only contraceptives are associated with short-term and long-term development of type 2 diabetes or glucose intolerance/prediabetes following a pregnancy with gestational diabetes? | - Compared to nonuse.; - Suggested rewording: “Does use of progestin-only contraceptives following a pregnancy complicated by GDM increase the risk of short- and long-term development of...“; - Are there parameters for short- and long-term development of type 2 diabetes? | 7.7 (7–9) | 6.7 (5–8) | -
III-Study needs and challenges | [underlined: Populations]; - Consistency in race/ethnicity (across studies); - Need for recruitment at time of GDM diagnosis; [underlined: Study Designs]; - Observational studies with ascertainment of covariates and confounders; - Random or purposeful sampling for more representative samples; [underlined: Analyses]; - Multivariate analyses for pooled estimates of risk; [underlined: Other Issues]; - Consistency in risk factors and their definitions (across studies); - Focus on specific categories of anthropometry (e.g., BMI, weight) and reproductive factors (e.g., parity); ([underlined: Note]—These study needs and challenges were not included in the online feedback process. They were discussed in the in-person meeting). | N/A ([underlined: Note]—These study needs and challenges were not included in the online feedback process. They were discussed in the in- person meeting). | N/A | N/A | - Current evidence is of poor quality.; - Studies were short-term and had low adjustment levels.
IV-1 | What is the accuracy of a single fasting blood glucose test compared to the full 2-hour 75-gm OGTT in diagnosing type 2 diabetes following a pregnancy with gestational diabetes? Does the accuracy of the fasting blood glucose test compared to the full 2- hour 75-gm OGTT vary with the postpartum testing interval in diagnosing type 2 diabetes following a pregnancy with gestational diabetes? | - Suggested rewording: “How does a single....fasting compare to the full ... in detecting ...? How does the postpartum testing interval affect the comparative detection rates between a single fasting ... and the full ...?” | 7.7 (6–9) | 6.8 (5–8) | - Compliance is an issue. If a patient will only use the less accurate test than that is better to collect data from the less accurate test vs. obtain no test results.
IV-2 | What is the accuracy of the HbA1c test compared to the 2-hour 75-gm OGTT or single fasting blood glucose test in diagnosing type 2 diabetes following a pregnancy with gestational diabetes? | - See previous wording suggestions | 7 (5–9) | 6.2 (4–8) | - No studies looked at HbA1c.
IV-3 | What is the reproducibility of the 2- hour 75-gram OGTT vs. a single fasting blood glucose test vs. a single HbA1c test in diagnosing type 2 diabetes following a pregnancy with gestational diabetes? | - Unclear how the three tests are being compared and which is the gold standard?; - Unclear what you mean by reproducibility ... do you mean consistency of results if repeated within the same patient? If so, then the last part of the sentence referring to “diagnosis” is unnecessary. | 7.2 (5–9) | 6.2 (3–8) | Not discussed at the in-person meeting. Only included in the online questionnaire.
IV-Study needs and challenges (for IV-1 & IV-2 only) | [underlined: Populations]; - Consistency in terms of race/ethnicity and future diabetes risk (family history of type 2 diabetes, prior GDM, etc.) (across studies); - Consistent protocols for recruitment of participants (across studies); [underlined: Other Issues]; - Do the screening test and interval of followup vary based on maternal risk factors other than GDM?; ([underlined: Note]—These study needs and challenges were not included in the online feedback process. They were discussed in the in-person meeting). | N/A ([underlined: Note]—These study needs and challenges were not included in the online feedback process. They were discussed in the in- person meeting). | N/A | N/A | -
Additional Overall Research Questions | - | - Should women with a history of GDM be treated as “once a GDM always a GDM” or should they be re- screened at each new pregnancy? What innovations in “delivery of care” models (e.g., “group care” within the clinical setting, alterations of frequency in visits) might improve outcomes of GDM? How does the relative “volatility” of glycemic control (even with same HbA1c) affect outcomes?; - If interested in progestin- only pills in women after GDM, it might be worth looking at other contraceptive methods (e.g., implants, intrauterine devices); - In addition to expanding psychosocial risk factors as listed earlier, access to care and health care disparities are other areas perhaps offering a relationship between GDM and the development of type 2 diabetes. | - | - | - Should include patient-centered outcomes like patient preference.; - Compliance is also important.; - Diet should also be taken into consideration including access to whole foods vs. packaged foods.; - Outcomes may be improved using group prenatal care which is used in the care of pregnant women without GDM. In support groups, the women follow each other’s progress.; - May improve outcomes by using an alternative clinic space and time. You could have a group of women meet at a gym and do exercise while they are waiting for their appointment.; - Must take into consideration transportation and healthcare disparities.; - Postpartum depression may be helped by followup visits because patients who require attention get it.; - No one has used information technology tools to track compliance.

* The wording of research questions and outcomes in this table and footnotes reflects the wording of research questions and outcomes as provided to the local stakeholders in the online feedback process. The wording of some research questions and outcomes was modified as appropriate before and after the in-person meeting on the basis of feedback received from the local stakeholders. The next version of wording of research questions (Delphi round 1) is provided in Appendix C.

Abbreviations: BMI=body mass index, EFW=estimated fetal weight, FBG=fasting blood glucose, GDM=gestational diabetes mellitus, HbA1c=hemoglobin A1c, HPA=hypothalamo-pituitary-adrenal, NICU=neonatal intensive care unit, OGTT=oral glucose tolerance test, PPG=postpartum glucose, RCT=randomized controlled trial, TZD=thiazoledinedione