# Results from Step 1 (Identification and Abstraction of Research Gaps from Evidence Report (2008) and Five Published Manuscripts) and Step 2 (Feedback from Authors of 2008 Evidence Report)

Key Question No. | Key Question Topic | Gap Areas | Specific Clarifications/Additional Gaps Received From Authors of 2008 Evidence Report
I | Benefits and harms of oral diabetes agents as compared to all types of insulin | [underlined: POPULATIONS]; - Racial distribution of populations studied needs to be reported.; - Glucose tolerance levels at baseline of populations studied needs to be reported.; [underlined: INTERVENTIONS & COMPARISONS]; - Any 2nd generation sulfonylurea vs. any insulin; - Glyburide vs. any insulin; - Metformin vs. any insulin; - Short-acting insulin vs. long-acting insulin; - Short-acting insulin vs. diet alone; [underlined: OUTCOMES]; - [underlined: Maternal—]Maternal weight, cesarean delivery, preeclampsia, hypoglycemia, perineal tears, operative vaginal delivery, and postpartum hemorrhage; - [underlined: Neonatal—B]irth trauma, birth weight, hypoglycemia, shoulder dystocia, congenital malformations, hyperbilirubinemia, large for gestational age, small for gestational age, macrosomia, neonatal intensive care unit admission, and perinatal mortality.; [underlined: SETTINGS]; - Determining optimal glucose thresholds for medication use in outpatient settings; [underlined: STUDY DESIGNS]; - Studies with power analyses and larger sample sizes; - RCTs with intention-to-treat analyses; - Studies with consistent and validated outcome measures across studies; - Prospective observational studies with low loss to follow up, adjusting for relevant covariates. | - While many outcome measures were included in these studies, future research needs should include consistent and validated outcome measures that are also clinically relevant. For example, hypoglycemia was defined in several different ways for the different studies, thus limiting the ability to combine results between studies. Hypoglycemia is an objective outcome measure that could be compared between studies. Other such objective, clinically relevant outcome measures should be established for future studies.; - For observational studies, practice patterns have evolved over the past few years, with more providers using oral antidiabetic agents. Observational studies may be possible now, but it is critical that adjustment for relevant covariates is included in such studies.
II | Benefits and harms of elective cesarean delivery or the choice of timing of induction | [underlined: POPULATIONS]; - Women with insulin-requiring (class A2) gestational diabetes; [underlined: INTERVENTIONS & COMPARISONS]; - Elective labor induction at term vs. expectant management at term; - Elective cesarean delivery at term vs. expectant management at term; - Elective labor induction or elective cesarean delivery at term vs. expectant management at term; [underlined: OUTCOMES]; - [underlined: Maternal] – Cesarean delivery, perineal tears, operative vaginal delivery, postpartum hemorrhage, and infection; - [underlined: Neonatal] – Shoulder dystocia, congenital malformations, birth trauma, hypoglycemia, hyperbilirubinemia, hypoglycemia, respiratory distress syndrome, neonatal mortality, birth weight, macrosomia, and large for gestational age; [underlined: SETTINGS]; - At term; - Less than 40 weeks gestation; [underlined: SUGGESTED STUDY DESIGNS]; - Well-designed observational studies with adjustment for other factors influencing labor management (e.g., socio-economic status) with low loss to follow up, adjusting for important covariates; - RCTs with intention-to-treat analyses; - Stratified analyses if diet-controlled and insulin-controlled patients are included. | - RCTs would be ideal. Only one RCT, with 200 patients has been completed on this topic. Although an RCT might be difficult to perform, it would be an important addition to the literature on this topic and intention-to-treat analyses can be used.; - There is also a great need for new prospective observational studies. Most of the previous studies are older and practice patterns have changed over time, making them somewhat less relevant. One important recommendation for future observational studies would be stratification by treatment, such as treatment with diet, insulin, and oral antidiabetic medications. Studies with large numbers of patients, for example at large tertiary care centers, would allow such stratification as well as more consistent treatment within groups. Carrying out the study at a large medical center would also allow the study to be completed in a shorter period of time, thus mitigating the impact of changing practice patterns.; - Adjustment for potential confounders is critical in any observational study performed. Because future research in this area will likely depend on observational studies, consistent outcome measures and consideration of confounders will be important to draw conclusions from such studies.
III | Risk factors associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes | [underlined: POPULATIONS]; - Racial distribution of populations studied need to be consistently reported; [underlined: RISK FACTORS]; - Maternal lifestyle risk factors; - Maternal anthropometry (BMI, weight); - Reproductive factors (e.g., parity); - Contraceptive use (especially progestin-only); - Behavioral factors, including breastfeeding, physical activity, postpartum weight retention; - Metabolic risk factors, including insulin sensitivity, HPA stress axis; [underlined: OUTCOMES]; - Development of type 2 diabetes mellitus; - Development of glucose intolerance; [underlined: SETTINGS]; - Clinical and non-clinical settings; [underlined: SUGGESTED STUDY DESIGNS]; - Well-designed observational (longitudinal cohort) studies with recruitment at the time of GDM diagnosis and with low loss to follow up. Multivariate analyses adjusting for important covariates needed.; - Sampling – random or purposeful sampling is recommended; - Consistent definitions for risk factors across studies (e.g. BMI thresholds); - Consistent anthropometric measures across studies; - Consistent and accepted definitions for short-term and long-term followup. | - Other risk factors that have not been examined include psychosocial factors (depression, perceived stress, etc.) and comorbidities related to increased risk of type 2 diabetes.; - Maternal lifestyle risk factor examples include physical activity and daily caloric intake.; - Metabolic risk factors should include subclinical hypercortisolism.; - Another risk factor to incude is postpartum depression or other depressive postpartum mental health disorders.; - In the outcome section “glucose intolerance” should be “glucose intolerance/prediabetes”; - Under suggested study designs the first bulleted point should be updated to the following: “Well-designed observational (longitudinal cohort) studies with recruitment at the time of GDM diagnosis and with low loss to follow up and collection of data on relevant risk factors noted above at the baseline exam on inception of the cohort.; - Settings outside of clinical setting should be included since 6 week followups for postpartum women are poor.
IV | Performance characteristics (sensitivity, specificity, and reproducibility) of tests for diagnosing type 2 diabetes following a pregnancy with gestational diabetes | [underlined: POPULATIONS]; - Racial distribution of populations studied need to be consistently reported; [underlined: INTERVENTIONS & COMPARISONS]; - Single FBG using ≥ 7.0 mmol/L threshold vs. OGTT (WHO 1999 criteria); - Other methods for diagnosis including HbA1c vs. OGTT vs. FBG; - Home blood glucose monitoring (FBG and random glucose readings); [underlined: OUTCOMES]; - Diagnosis of type 2 diabetes mellitus; - Reproducibility of tests (single FBG, OGTT using WHO 1999 criteria); [underlined: SETTINGS]; - Postpartum period and beyond; - What are the optimal frequency screening intervals? (schedule X vs. schedule Y); - Should the screening test and interval of followup vary based on maternal risk factors other than GDM?; [underlined: SUGGESTED STUDY DESIGNS]; - Longitudinal studies; - RCTs of different screening tests (FBG vs. complete OGTT) to determine diagnostic effectiveness of screening test, patient adherence, and patient satisfaction | - Would consider combining suggested study designs to state longitudinal studies and RCTS in one sentence. Could consider adding cluster randomized trials since these are more effectiveness-based than standard RCTs.
General Research Gaps (Not Specific to Any Key Question) | - | [underlined: INTERVENTIONS & COMPARISONS]; - Effective diagnostic tests for glucose intolerance (not just type 2 diabetes mellitus) in women with history of GDM, even in non-hospitalized patients; - Treatment choice (insulin, glyburide, metformin, combinations) and development of type 2 diabetes mellitus; - Interventions to improve compliance with postpartum screening for type 2 diabetes mellitus in women with history of GDM.; - Studies to develop strategies and technology to track and monitor provider compliance with postpartum glucose tolerance testing in women with history of GDM; - RCTs to assess the efficacy of lifestyle interventions in women with history of GDM for prevention of type 2 diabetes mellitus and obesity; - RCTs of comparative effectiveness of strategies (medication, behavioral) to prevent obesity, or glucose intolerance (fasting glucose intolerance, insulin resistance, type 2 diabetes mellitus) in women with GDM; - Studies to develop strategies and technology to disseminate educational materials and strategies for prevention of type 2 diabetes mellitus in women with history of GDM; [underlined: SETTINGS]; - Postpartum period; - Non-hospitalized patients; [underlined: SUGGESTED STUDY DESIGNS]; - Observational studies; - RCTs. | - Could add after treatment choice thiazolidinediones, exenetide, and januvia to the list.

Abbreviations: BMI=body mass index, GDM=gestational diabetes mellitus, HbA1c =hemoglobin A1c, HPA=hypothalamo-pituitary-adrenal, OGTT=oral glucose tolerance test, RCT=randomized controlled trial, WHO=World Health Organization