# Results

## Phase 1 Updating the 2008 SER Literature Review

Our search updating the 2008 evidence review was executed in January 2010. From PubMed, we identified 234 items for further review; EMBASE yielded 41 items; CINAHL yielded 89 items; and the Cochrane database yielded 18 citations. After eliminating duplicates, 386 citations comprised our pool of publications to screen of which 55 publications, representing 52 populations, were ultimately relevant to describing research completed since the 2008 report. Fifty articles pertained to KQ 1, 19 to KQ 2, 18 to KQ 3, seven to KQ 4, and one to KQ 5 (Figure 3) .

Table 9 provides an overview of these 55 publications,14–68 representing 52 populations. They were most frequently retrospective cohorts (n = 24) conducted in the United States (n = 27) with participants recruited most often from the community (n = 20). Funding for most of the current studies was from national sources, including various components of the National Institutes of Health in the United States and the Ministry of Health, Labor, and Welfare in Japan. The focus of all 52 studies was to determine the influence of prepregnancy weight or BMI. The measures of prepregnancy weight/BMI varied from measurements taken at the first prenatal booking to self-report of prepregnancy measurements. Risk of cesarean delivery was the focus for approximately one-fourth of all of the included studies, while nearly two-thirds reported infant and child health outcomes, including APGAR scores and birthweight.

Table 9 Summary of new publications in the maternal weight gain literature since 2008 review

Characteristic | Populations Studied
Characteristic | US (n = 27) | Europe (n = 18) | Asia (n = 2) | Other (n = 5) | Total (n = 52)
Study type
Case series | 1 | 1 | 0 | 0 | 2
Retrospective cohort | 13 | 8 | 1 | 2 | 24
Prospective cohort | 10 | 8 | 1 | 1 | 20
Randomized controlled trials | 1 | 1 | 0 | 1 | 3
SER/meta-analyses | 2 | 0 | 0 | 1 | 3
Focus of research
Influence of prepregnancy BMI/weight | 27 | 18 | 2 | 5 | 52
Weight gain and cesarean risk | 5 | 5 | 0 | 2 | 12
Infant/child health outcomes | 15 | 11 | 2 | 5 | 33
Participant source
Academic single site | 4 | 3 | 1 | 2 | 10
Academic multisite | 3 | 1 | 1 | 0 | 5
Community | 8 | 12 | 0 | 0 | 20
Database | 11 | 4 | 0 | 2 | 17
Funding source
National (NIH, MRC, etc.) | 18 | 5 | 1 | 3 | 27
Foundation/other | 6 | 9 | 0 | 2 | 17
Not reported | 3 | 4 | 1 | 0 | 8

Only two studies of direct comparisons met our inclusion/exclusion criteria. They include a study of dietary consultations by a trained dietitian (ten 1-hour sessions) vs. usual care (no dietary consultations)56 and another of dietary and lifestyle counseling vs. usual prenatal care.16

## Phase 2 Steps of the Modified Delphi Process

Step 1. Building on the nidus of 37 questions from prior work. During the snowballing process the stakeholders increased the initial panel of items from 37 to a total of 50 candidate research questions that would advance the state of the science and fill important knowledge gaps. The research questions captured both methodologic needs for advancement of the science and knowledge gaps that must be filled to inform and ultimately guide clinical care. The research questions also encompassed a wide range of specific methods for measurement of maternal weight, weight gain, and body habitus, as well as a range of specific outcomes that could be broadly grouped into maternal, fetal, neonatal, and childhood outcomes.

Table 10 Initial list of future research needs

General Evidence Gaps
Is total weight gain or rate of weight gain during pregnancy associated with (1) birth outcomes, (2) infant health outcomes, and (3) maternal health outcomes?
What factors confound the relationship between gestational weight gain (overall and patterns) and birth outcomes?
What factors modify the relationship between gestational weight gain (overall and patterns) and birth outcomes?
What is the impact of age on the relationship of weight gain and pregnancy outcomes?
Does age at menarche modify the relationship of weight gain and pregnancy outcomes?
Does weight gain above thresholds defined in the 2009 IOM body mass index (BMI) guidelines contribute to the following:; a. antepartum complications; b. postpartum complications; c. longer-term maternal and infant complications
Does weight gain below thresholds defined in the 2009 IOM body mass index (BMI) guidelines contribute to the following:; a. antepartum complications; b. postpartum complications; c. longer-term maternal and infant complications
Do weight loss thresholds defined in the 2009 IOM body mass index (BMI) guidelines contribute to the following:; a. antepartum complications; b. postpartum complications; c. longer-term maternal and infant complications
How do these relationships vary by sociodemographic characteristics (i.e., race and age)?
What are the harms or benefits of offering the same weight gain recommendations to all pregnant women, irrespective of age and body weight considerations (e.g., pregravid weight, actual body weight at a particular time point, or optimal body weight)? (AHRQ 2008)
Which anthropometric tools are most appropriate for determining adiposity and are appropriate during pregnancy?
What are the risks and benefits of measuring adiposity for (1) clinical management of weight gain during pregnancy and (2) evaluation of the relationship between weight gain and outcomes of pregnancy?
What are the level of knowledge, attitudes, and self-efficacy of women regarding gestational weight gain? (AHRQ 2008)
Does weight gain influence lactation initiation and maintenance?
Does parity modify the relationship of weight gain and pregnancy outcomes?
Do genetic factors influence the relationship between weight gain and pregnancy outcomes?
Is there an interaction of stature and weight gain? (AHRQ 2008)
What is the impact of total weight gain vs. rate of weight gain vs. timing of weight gain on pregnancy outcomes? (AHRQ 2008)
What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes? (AHRQ 2008)
What are the optimal weight gains for obese women? (AHRQ 2008)
What research and databases describe the distribution of maternal weight (prior to, during, and after pregnancy) among different populations of women in the United States? (NRC-IOM 2007)
What research and databases inform understanding of the effects of different weight patterns (including underweight and overweight) during pregnancy on maternal and child health outcomes? (NRC-IOM 2007)
Interventions
Do women receive accurate weight gain guidance by their prenatal clinicians; whether clinicians have the knowledge, attitudes, and skills necessary to provide appropriate weight gain guidance? (AHRQ 2008)
What research has been conducted to describe the individual, community, and health care system factors that impede or foster compliance with recommended GWG guidelines? (NRC-IOM 2007)
What intervention(s) are effective for achieving recommended maternal weight gain?
What methods are effective for helping women understand goals for weight gain in pregnancy?
What role does physical activity play in achieving recommended maternal weight gain?
What role does nutrition play in achieving recommended maternal weight gain?
Standardization Issues
How should outliers in pregravid weight, gestational weight gain, postpartum weight, and maternal height be handled in analyses?
What is the need for standardization of research measures to advance the field?
Policy
How accurate is self-reported compared to measured weight (prepregnancy, in pregnancy, and post-partum) in all populations and among women of varying pregravid weights and gestational ages?
What are the tests of the reliability of self-reported weights in pregnancy by age, parity, and BMI? (AHRQ 2008)
What opportunities exist for Title V maternal and child health programs to build on this knowledge to help childbearing women achieve and maintain recommended weight? (NRC-IOM 2007)
What future research and data collection efforts could improve the efforts of Title V programs to support women from different racial and ethnic backgrounds in their efforts to comply with recommended weight guidelines and to improve their maternal health? (NRC-IOM 2007)
Measurement
Is rate of weight gain, adequacy of rate of weight gain, or total weight gain superior for predicting adverse outcomes?
What are the preferred anthropometric measurements for predicting outcomes of interest? (AHRQ 2008)
Does direct measurement of body fat (prepregnancy, in pregnancy, post-partum) contribute to the understanding of outcomes?

Step 2. Initial scoring and item reduction. The full list of 50 items, 12 measurement approaches, and eight outcome categories were compiled and presented to the stakeholders for assigning priority scores as described in methods.

Eliminating those items that were low scoring resulted in a total of 27 remaining research questions. All questions related to issues of policy were eliminated at this stage. In addition, among the 12 measurement standards and eight outcomes, the lowest ranking one-third of each list was eliminated resulting in eight and five items respectively progressing into the next round. The complete results of the first round of scoring in order to rank items by priority are included in Appendix C.

Step 3. Final ranking of reduced list of items. In the next stage of ranking, respondents re-ranked the candidate 27 research questions. They also ranked the remaining eight measures and five outcomes of maternal weight gain as those with the greatest value for use in future research.

Prioritization of measures. Respondents were asked to rank the measures, with “1” (or “first place”) as the highest ranking and “8” as the lowest. The result of this ranking was selection of “total weight gain from prepregnancy to end of pregnancy” as the highest priority measure of maternal weight gain, followed by “prepregnancy baseline weight/BMI” and “change body/body fat composition” (Table 11).

Table 11 Prioritization of measures of maternal weight gain for use in future research

Measure | Total points | Rank
Total weight gain from prepregnancy to end of pregnancy | 47 | 1st
Prepregnancy baseline weight/BMI | 63 | 2nd
Change in body/body fat composition | 65 | 3rd
Pattern of weight gain across pregnancy as a statistical trend line or function | 79 | 4th
Total weight gain from first trimester to end of pregnancy | 82 | 5th
Pattern of weight gain across trimesters | 82 | 6th
Rate of weight gain | 84 | 7th
Change in BMI from prepregnancy to end of pregnancy | 88 | 8th

Prioritization of outcomes. Participants were asked to rank the five remaining outcomes. The final prioritization ranked “maternal postpartum” and “child health” outcomes as the most important outcomes related to maternal weight gain.

Table 12 Prioritization of specific outcomes to study in relation to maternal weight gain

Type of outcome | Total points | Rank
Maternal postpartum outcomes | 43 | 1st
Child health outcomes | 46 | 2nd
Infant health outcomes | 47 | 3rd
Development of gestational diabetes | 52 | 4th
Fetal outcomes | 52 | 5th

In the next sections we summarize the prioritization of research questions within the classes that were used initially to group them. Then we present the highest priority items across all the classes—in other words the highest ranking items from the entire panel of research questions.

General evidence gaps. The original list of general evidence gaps contained 22 questions. After the snowballing phase 29 questions were included in this class. At the conclusion of the first stage of ranking 12 questions were eliminated – leaving 17 to be ranked in the second phase. The table below shows the resulting score totals from the second phase, across the four domains: overall importance, clinical utility, feasibility, and potential to advance science. The table is arranged by highest overall importance score. In terms of clinical utility, “Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?” scored highest among general evidence gaps. For feasibility, “What research studies and databases are available to describe the distribution of maternal weight gain (prior to, during and after pregnancy) among different populations of women in the US?” scored highest among general evidence gaps. Finally, for potential to advance the science “What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes?” scored highest among general evidence gaps.

Table 13 Prioritization of general evidence gaps by overall importance score

Question | Overall Importance | Clinical Utility | Feasibility | Advance Science
What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes? | 124 | 112 | 100 | 122
Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]? | 123 | 117 | 109 | 115
Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]? | 119 | 112 | 114 | 117
What factors confound the relationship between [weight gain in pregnancy] and [outcomes]? | 117 | 106 | 101 | 107
What physiologic or clinical factors modify the relationship between [weight gain in pregnancy] and [outcomes]? | 116 | 102 | 96 | 113
Does physical activity [metabolic expenditure] confound the relationship between [weight gain in pregnancy] and [outcomes]? | 114 | 108 | 107 | 112
What are the optimal gestational weight gains for women with varying degrees of prepregnancy obesity? | 114 | 114 | 97 | 112
Does gestational weight gain above targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer- term maternal and infant complications)? | 113 | 117 | 110 | 112
Does gestational weight gain below targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer- term maternal and infant complications)? | 110 | 117 | 110 | 112
What are the harms and benefits of offering standardized weight gain recommendations to all pregnant women? | 110 | 111 | 85 | 105
Does pregravid health status confound the relationship between [weight gain in pregnancy] and [outcomes]? | 109 | 101 | 83 | 107
What is the relative impact of total weight gain vs. rate of weight gain vs. timing of weight gain (by trimester) on pregnancy outcomes? | 108 | 109 | 99 | 106
What is the general health literacy (i.e., the level of knowledge, attitudes and self-efficacy) of women regarding gestational weight gain? | 106 | 103 | 109 | 101
Which anthropometric tools are most appropriate for determining adiposity in pregnant women? | 104 | 99 | 99 | 105
Does use of insulin or other diabetes medications modify the relationship between [weight gain in pregnancy] and [outcomes]? | 102 | 110 | 110 | 109
What research studies and databases are available to describe the distribution of maternal weight gain (prior to, during and after pregnancy) among different populations of women in the US? | 102 | 93 | 117 | 96
What research studies and databases are available to inform our understanding of the effects of different weight patterns (including underweight and overweight) during pregnancy on maternal and child health outcomes? | 92 | 87 | 108 | 95

For addressing general evidence gaps as listed above, the three research questions with the highest priority scores for overall importance were:

1. What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes?
2. Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?
3. Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]?

Averaging across all four domains, the three research questions with the highest priority scores for addressing general evidence gaps were:

1. Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?
2. Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]?
3. What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes?

Targets for interventions. Research gaps identified in prior reports or during snowballing that reflected targets for intervention, such as knowledge and attitudes, or intent to assess interventions for modifying weight gain were grouped together as a class of survey items. The original list of gaps related to interventions contained six questions. After the snowballing phase, seven questions were included in this class. At the conclusion of the first stage of ranking one question was eliminated—leaving six to be ranked in the second phase. The table below shows the score totals across the four domains: overall importance, clinical utility, feasibility, and potential to advance science. The highest scoring questions were “Do prenatal care providers have the necessary knowledge, attitudes, and skills to provide appropriate weight gain guidance to women?” scored highest for both clinical utility and feasibility, while “What interventions are effective for the outcome of maternal weight gain within the recommended range(s)?” scored highest for the potential to advance science.

Table 14 Prioritization of intervention gaps by overall importance ranking

Question | Overall Importance | Clinical Utility | Feasibility | Advance Science
How does physical activity affect maternal weight gain? | 111 | 110 | 97 | 102
What interventions are effective for the outcome of maternal weight gain within the recommended range(s)? | 108 | 107 | 101 | 104
Do prenatal care providers have the necessary knowledge, attitudes, and skills to provide appropriate weight gain guidance to women? | 104 | 113 | 104 | 95
How does total caloric intake and dietary composition of caloric intake affect maternal weight gain? | 99 | 96 | 78 | 98
What methods are effective for helping women acquire knowledge and understanding of the goals for weight gain, and skills for controlling weight gain? | 93 | 95 | 86 | 82
What research has been conducted to describe the individual, community, and health care system factors that impede or foster adherence to recommended gestational weight gain guidelines? | 89 | 88 | 97 | 85

For addressing intervention gaps as listed above, the three research questions with the highest priority scores for overall importance were:

1. How does physical activity affect maternal weight gain?
2. What interventions are effective for the outcome of maternal weight gain within the recommended range(s)?
3. Do prenatal care providers have the necessary knowledge, attitudes, and skills to provide appropriate weight gain guidance to women?

Averaging across all for domains, the three research questions with the highest priority scores for addressing intervention gaps were:

1. How does physical activity affect maternal weight gain?
2. What interventions are effective for the outcome of maternal weight gain within the recommended range(s)?
3. Do prenatal care providers have the necessary knowledge, attitudes, and skills to provide appropriate weight gain guidance to women?

Standardization issues. Research gaps identified in prior reports or during snowballing that reflected targets for standardization related to measures and the overall lack of standardization related to maternal weight gain were included in this class of items. The original list of gaps related to standardization issues contained two questions. After the snowballing phase, six questions were included in this class. At the conclusion of the first stage of ranking four questions were eliminated—leaving two to be ranked in the second phase. The table below shows the score totals across the four domains: overall importance, clinical utility, feasibility, and potential to advance science. “What is the need for standardization of research measures to advance the field of research related to weight gain in pregnancy?” ranked highest across all of the domains.

Table 15 Prioritization of standardization issues by overall importance ranking

Question | Overall Importance | Clinical Utility | Feasibility | Advance Science
What is the need for standardization of research measures to advance the field of research related to weight gain in pregnancy? | 90 | 76 | 95 | 84
Is there a lack of standardization in current research in terms of maternal weight gain measures? | 70 | 62 | 82 | 72

Policy. The original list of research questions and the snowballing phase resulted in four questions related to policy issues. After the initial ranking phase all four questions were eliminated from the ranking because none of the questions received the required number of 9s or 10s to remain on the list.

Measurement. Research gaps identified in prior reports or during snowballing that reflected targets for measurement issues were included in this class of items. The original list of gaps related to measurement issues contained three questions. After the snowballing phase, four questions were included in this class. At the conclusion of the first stage of ranking two questions were eliminated—leaving two to be ranked in the second phase. The table below shows the score totals across the four domains: overall importance, clinical utility, feasibility, and potential to advance science. “What are the preferred anthropometric measurements for predicting birth, maternal, and infant outcomes?” ranked highest across all of the domains, except for clinical utility.

Table 16 Prioritization of measurement research questions

Question | Overall Importance | Clinical Utility | Feasibility | Advance Science
What are the preferred anthropometric measurements for predicting birth, maternal, and infant outcomes? | 90 | 86 | 78 | 91
Is rate of weight gain, change in BMI, adequacy of rate of weight gain, or total weight gain superior for predicting adverse birth, maternal, and infant outcomes? | 86 | 87 | 76 | 84

Across all of the classes, the highest priority questions by overall importance were:

1. What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes?
2. Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?
3. Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]?
4. What factors confound the relationship between [weight gain in pregnancy] and [outcomes]?
5. What physiologic or clinical factors modify the relationship between [weight gain in pregnancy] and [outcomes]?

The questions with the most clinical utility were:

1. Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?
2. Does gestational weight gain above targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?
3. Does gestational weight gain below targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?
4. What are the optimal gestational weight gains for women with varying degrees of prepregnancy obesity?
5. Do prenatal care providers have the necessary knowledge, attitudes, and skills to provide appropriate weight gain guidance to women?

The questions rated as highest priority based on feasibility were:

1. What research studies and databases are available to describe the distribution of maternal weight gain (prior to, during and after pregnancy) among different populations of women in the US?
2. Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]?
3. Does gestational weight gain above targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?
4. Does gestational weight gain below targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?
5. Does use of insulin or other diabetes medications modify the relationship between [weight gain in pregnancy] and [outcomes]?

The future research questions rated as highest priority for advancing the science relating maternal weight gain and outcomes were (the final four items received the same score):

1 What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes?
2 Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]?
3 Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?
4 What physiologic or clinical factors modify the relationship between [weight gain in pregnancy] and [outcomes]?
5 Does physical activity [metabolic expenditure] confound the relationship between [weight gain in pregnancy] and [outcomes]?
5 Does gestational weight gain above targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?
5 Does gestational weight gain below targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?
5 What are the optimal gestational weight gains for women with varying degrees of prepregnancy obesity?

## Highest Priority Research Questions

The top 5 questions by highest average score across all four domains were:

1. Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?
2. Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]?
3. What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes?
4. Does gestational weight gain above targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?
5. Does gestational weight gain below targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?

## Phase 3 Optimal Research Designs To Address Top Priority Questions

After the list of research needs and knowledge gaps had been prioritized, we engaged stakeholders in a conference call in order to discuss with them the study designs that would be the most successful in answering the research questions needed to fill the related gaps in knowledge. During the call, stakeholders provided feedback on the revised analytic framework (Figure 4). These revisions reflect the complex interaction between the “Social/Built/Natural & Life-Stage Environment” and “Maternal Factors.”

Figure 3 Disposition of articles for updating status of maternal weight gain literature

Through a flow chart, Figure 3 depicts the process of identifying relevant articles during a literature search to update information on maternal weight gain. Database searching identified 382 records, and hand searching identified an additional 4 records, for a total of 386. Further analysis excluded 169 records, and the other 217 were full-text articles assessed for eligibility. Of those, 162 articles were excluded for 10 listed reasons and 55 articles were included.

In addition stakeholders suggested next steps and general study designs that they felt would be essential to moving the science related to the outcomes of weight gain in pregnancy forward. These suggestions included:

- Developing consensus about standards for methods of collecting prepregnancy weight and height as well as other body composition and anthropometric measures.
- Maximizing use of existing data collection infrastructure (new birth certificate formats, Behavioral Risk Factor Surveillance System [BRFSS], and Pregnancy Risk Assessment Monitoring System [PRAMS]) to develop national surveillance studies with large sample size among representative populations.
- Using current WIC (Women, Infants, and Children) infrastructure to conduct postpartum followup to include weighing pregnant and non-pregnant women consistently to allow for accurate baseline data for any subsequent pregnancies.
- Conducting national surveys, with possible inclusion of questions on BRFSS instruments, in order to determine knowledge and attitudes among women about weight gain and their experiences in care.
- Conducting similar evaluations of the knowledge, attitudes, and perceived barriers of providers that inhibit addressing maternal weight and weight gain.
- Launching intervention studies that include efforts to change the built environment, including community-based interventions (e.g., increasing access to gyms and community centers in neighborhoods where it is not safe to exercise outside by distributing coupons/incentives to facilities)
- Coupling community-based interventions with individual-level interventions such as behavioral counseling and nutrition education or innovative means of prenatal care delivery such as centering (group prenatal care).
- Designing randomized controlled trials of promising interventions with large enough scope to make the causal relationship between weight gains above guideline thresholds and poor outcomes (maternal and child) explicitly testable.
- Collecting longer-term outcomes, such as child health and development data and study of maternal weight trajectories between and after pregnancies with more rigorous measures than those available to date.
- Strategizing means to assure a focus on maternal weight gain measures in upcoming national surveys including the National Children’s Study.

Figure 4 Final modified analytic framework for future research

Figure 4 depicts the final modified analytic framework for future research on maternal weight gain. Similar to Figure 1, a flow chart consisting of pathways of boxes and arrows indicates the influence of individual maternal factors and societal factors on maternal weight gain. Research gaps are described within seven dashed circles, with arrows pointing to the related factors. Twelve general research needs not related to specific factors but having broad influence on weight gain and outcomes are listed in a dashed box at the bottom. Compared with Figure 1, Figure 4 provides less-detailed information about specific maternal and societal factors influencing weight gain.

Social/Built/Natural and Life-stage Environment includes the following domains and sub-domains:

- Societal/Institutional
  - Media
  - Culture and acculturation
  - Health services
  - Policy
- Environmental
  - Altitude
  - Environmental toxicants
  - Natural and man-made disasters
- Neighborhood/Community
  - Access to healthy foods
  - Opportunities for physical activity
- Interpersonal/Family
  - Family status
  - Marital status
  - Partner and family support

Maternal factors include, but are not limited to the following:

- Age
- Race
- Health status: pre-existing conditions and pregnancy complications
- Genetic characteristics
- Developmental programming
- History of restrained eating
- Sociodemographic (SES, food insecurity)
- Smoking
- Substance abuse
- Prenatal care
- Prepregnancy BMI
- Psychological (depression, stress)
- Pregnancy intendedness
- Weight gain recommendations