# References

1 IOM (Institute of Medicine). Weight gain during pregnancy: reexamining the guidelines. Washington, DC. The National Academies Press. 2009.
2 Cogswell ME, Serdula MK, Hungerford DW, et al. Gestational weight gain among average-weight and overweight women—what is excessive?. Am J Obstet Gynecol. Feb. 1995;172(2 Pt 1):705-712. [pmid: 7856711].
3 Saldana TM, Siega-Riz AM, Adair LS, et al. The relationship between pregnancy weight gain and glucose tolerance status among black and white women in central North Carolina. Am J Obstet Gynecol. Dec. 2006;195(6):1629-1635. [pmid: 16824460].
4 Kiel DW, Dodson EA, Artal R, et al. Gestational weight gain and pregnancy outcomes in obese women: how much is enough?. Obstet Gynecol. Oct. 2007;110(4):752-758. [pmid: 17906005].
5 Finkelstein EA, Fiebelkorn IC, Wang G. National medical spending attributable to overweight and obesity: how much, and who’s paying?. Health Aff (Millwood). Jan–Jun. Suppl Web Exclusives. 2003:W3219-3226.
6 Finkelstein EA, Ruhm CJ, Kosa KM. Economic causes and consequences of obesity. Annu Rev Public Health. 2005;26:239-257. [pmid: 15760288].
7 Hedley AA, Ogden CL, Johnson CL, et al. Prevalence of overweight and obesity among US children, adolescents, and adults, 1999–2002. JAMA. Jun. 16. 2004;291(23):2847-2850. [pmid: 15199035].
8 Ogden CL, Carroll MD, Curtin LR, et al. Prevalence of overweight and obesity in the United States, 1999–2004. JAMA. Apr. 5. 2006;295(13):1549-1555. [pmid: 16595758].
9 Institute of Medicine. Influence of Pregnancy Weight on Maternal and Child Health: Workshop Report Committee on the Impact of Pregnancy Weight on Maternal and Child Health. Washington, DC. 2007.
10 Kramer MS, Morin I, Yang H, et al. Why are babies getting bigger? Temporal trends in fetal growth and its determinants. J Pediatr. Oct. 2002;141(4):538-542. [pmid: 12378194].
11 Hamilton BE, Martin JA, Ventura SJ, et al. Births: preliminary data for 2004. Natl Vital Stat Rep. Dec. 29. 2005;54(8):1-17.
12 Keeney S, Hasson F, McKenna HP. A critical review of the Delphi technique as a research methodology for nursing. Int J Nurs Stud. Apr. 2001;38(2):195-200. [pmid: 11223060].
13 Helmer-Hirschberg O. The Delphi Method for Systematizing Judgements About the Future. Los Angeles, CA. Institute for Government Affairs. 1966.
14 Abayomi J, Watkinson H, Topping J, et al. Obesity and underweight among first trimester pregnant women. British Journal of Midwifery. 2007;15(3):143-147.
15 Althuizen E, van Poppel MN, Seidell JC, et al. Correlates of absolute and excessive weight gain during pregnancy. J Womens Health (Larchmt). Oct. 2009;18(10):1559-1566. [pmid: 19788365].
16 Asbee SM, Jenkins TR, Butler JR, et al. Preventing excessive weight gain during pregnancy through dietary and lifestyle counseling: a randomized controlled trial. Obstet Gynecol. Feb. 2009;113(2 Pt 1):305-312. [pmid: 19155899].
17 Ay L, Kruithof CJ, Bakker R, et al. Maternal anthropometrics are associated with fetal size in different periods of pregnancy and at birth. The Generation R Study. BJOG. Jun. 2009;116(7):953-963. [pmid: 19522798].
18 Bruno CJ, Locke R, Mackley A, et al. The association between maternal body mass index and severity of neonatal illness in very low birth weight infants. J Matern Fetal Neonatal Med. Jul. 2009;22(7):560-564. [pmid: 19488942].
19 Bulik CM, Von Holle A, Siega-Riz AM, et al. Birth outcomes in women with eating disorders in the Norwegian Mother and Child cohort study (MoBa). Int J Eat Disord. Jan. 2009;42(1):9-18. [pmid: 18720472].
20 Chasan-Taber L, Schmidt MD, Pekow P, et al. Predictors of excessive and inadequate gestational weight gain in Hispanic women. Obesity (Silver Spring). Jul. 2008;16(7):1657-1666. [pmid: 18451771].
21 Chereshneva M, Hinkson L, Oteng-Ntim E. The effects of booking body mass index on obstetric and neonatal outcomes in an inner city UK tertiary referral centre. Obstetric Medicine. 2008;1(1):88-91.
22 Chu SY, Bachman DJ, Callaghan WM, et al. Association between obesity during pregnancy and increased use of health care. N Engl J Med. Apr. 3. 2008;358(14):1444-1453. [pmid: 18385496].
23 Crane JM, White J, Murphy P, et al. The effect of gestational weight gain by body mass index on maternal and neonatal outcomes. J Obstet Gynaecol Can. Jan. 2009;31(1):28-35. [pmid: 19208280].
24 Dietz PM, Callaghan WM, Sharma AJ. High pregnancy weight gain and risk of excessive fetal growth. Am J Obstet Gynecol. Jul. 1. 2009;201(1):51e-6. [pmid: 19576373].
25 Dietz PM, Callaghan WM, Smith R, et al. Low pregnancy weight gain and small for gestational age: a comparison of the association using 3 different measures of small for gestational age. Am J Obstet Gynecol. Jul. 2009;201(1):53e1-7. [pmid: 19576374].
26 Dodd JM, Crowther CA, Robinson JS. Dietary and lifestyle interventions to limit weight gain during pregnancy for obese or overweight women: a systematic review. Acta Obstet Gynecol Scand. 2008;87(7):702-706. [pmid: 18607830].
27 Fortner RT, Pekow P, Solomon CG, et al. Prepregnancy body mass index, gestational weight gain, and risk of hypertensive pregnancy among Latina women. Am J Obstet Gynecol. Feb. 2009;200(2):167 e1-7. [pmid: 19070831].
28 Geelhoed JJ, VANO-G L, Verburg BO, et al. Maternal anthropometrics in pregnancy are associated with left ventricular mass in infancy. The generation R study. Pediatr Res. Jan. 2008;63(1):62-66. [pmid: 18043515].
29 Getahun D, Kaminsky LM, Elsasser DA, et al. Changes in prepregnancy body mass index between pregnancies and risk of primary cesarean delivery. American Journal of Obstetrics and Gynecology. 2007;197:376.e1-376.e7. [pmid: 17904966].
30 Groth SW. The long-term impact of adolescent gestational weight gain. Res Nurs Health. Apr. 2008;31(2):108-118. [pmid: 18181102].
31 Heimonen A, Janket SJ, Kaaja R, et al. Oral inflammatory burden and preterm birth. J Periodontol. Jun. 2009;80(6):884-891. [pmid: 19485817].
32 Helmreich RJ, Hundley V, Varvel P. The effect of obesity on heart rate (heart period) and physiologic parameters during pregnancy. Biol Res Nurs. Jul. 2008;10(1):63-78. [pmid: 18647761].
33 Hoff GL, Cai J, Okah FA, et al. Pre-pregnancy overweight status between successive pregnancies and pregnancy outcomes. J Womens Health (Larchmt). Sep. 2009;18(9):1413-1417. [pmid: 19698074].
34 Hutcheon JA, Platt RW. The impact of past pregnancy experience on subsequent perinatal outcomes. Paediatr Perinat Epidemiol. Jul. 2008;22(4):400-408. [pmid: 18578754].
35 Jeffries K, Shub A, Walker SP, et al. Reducing excessive weight gain in pregnancy: a randomised controlled trial. Med J Aust. Oct. 19. 2009;191(8):429-433. [pmid: 19835535].
36 Joseph NP, Hunkali KB, Wilson B, et al. Pre-pregnancy body mass index among pregnant adolescents: gestational weight gain and long-term post partum weight retention. J Pediatr Adolesc Gynecol. Aug. 2008;21(4):195-200. [pmid: 18656073].
37 Kessler J, Rasmussen S, Godfrey K, et al. Longitudinal study of umbilical and portal venous blood flow to the fetal liver: low pregnancy weight gain is associated with preferential supply to the fetal left liver lobe. Pediatr Res. Mar. 2008;63(3):315-320. [pmid: 18338440].
38 Kramer MS, Kakuma R. Energy and protein intake in pregnancy [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4.
39 Loetscher KC, Selvin S, Zimmermann R, et al. Ethnic-cultural background, maternal body size and pregnancy outcomes in a diverse Swiss cohort. Women Health. 2007;45(2):25-40. [pmid: 18019284].
40 Magriples U, Kershaw TS, Rising SS, et al. The effects of obesity and weight gain in young women on obstetric outcomes. Am J Perinatol. May. 2009;26(5):365-371. [pmid: 19085680].
41 Mamun AA, O’Callaghan M, Callaway L, et al. Associations of gestational weight gain with offspring body mass index and blood pressure at 21 years of age: evidence from a birth cohort study. Circulation. Apr. 7. 2009;119(13):1720-1727. [pmid: 19307476].
42 McLaughlin CC, Baptiste MS, Schymura MJ, et al. Perinatal risk factors for neuroblastoma. Cancer Causes Control. Apr. 2009;20(3):289-301. [pmid: 18941915].
43 Miletic T, Stoini E, Mikulandra F, et al. Effect of parental anthropometric parameters on neonatal birth weight and birth length. Coll Antropol. Dec. 2007;31(4):993-997. [pmid: 18217447].
44 Morgen CS, Bjork C, Andersen PK, et al. Socioeconomic position and the risk of preterm birth--a study within the Danish National Birth Cohort. Int J Epidemiol. Oct. 2008;37(5):1109-1120. [pmid: 18577529].
45 Nohr EA, Vaeth M, Baker JL, et al. Combined associations of prepregnancy body mass index and gestational weight gain with the outcome of pregnancy. Am J Clin Nutr. Jun. 2008;87(6):1750-1759. [pmid: 18541565].
46 Nohr EA, Vaeth M, Baker JL, et al. Pregnancy outcomes related to gestational weight gain in women defined by their body mass index, parity, height, and smoking status. Am J Clin Nutr. Nov. 2009;90(5):1288-1294. [pmid: 19759164].
47 Ogonowski J, Miazgowski T, Czeszynska MB, et al. Factors influencing risk of macrosomia in women with gestational diabetes mellitus undergoing intensive diabetic care. Diabetes Res Clin Pract. Jun. 2008;80(3):405-410. [pmid: 18342386].
48 Oken E, Rifas-Shiman SL, Field AE, et al. Maternal gestational weight gain and offspring weight in adolescence. Obstet Gynecol. Nov. 2008;112(5):999-1006. [pmid: 18978098].
49 Rodriguez A, Miettunen J, Henriksen TB, et al. Maternal adiposity prior to pregnancy is associated with ADHD symptoms in offspring: evidence from three prospective pregnancy cohorts. Int J Obes (Lond). Mar. 2008;32(3):550-557. [pmid: 17938639].
50 Rudra CB, Frederick IO, Williams MA. Pre-pregnancy body mass index and weight gain during pregnancy in relation to preterm delivery subtypes. Acta Obstet Gynecol Scand. 2008;87(5):510-517. [pmid: 18446533].
51 Salihu HM, Mbah AK, Alio AP, et al. Low pre-pregnancy body mass index and risk of medically indicated versus spontaneous preterm singleton birth. Eur J Obstet Gynecol Reprod Biol. Jun. 2009;144(2):119-123. [pmid: 19328619].
52 Schiessl B, Beyerlein A, Lack N, et al. Temporal trends in pregnancy weight gain and birth weight in Bavaria 2000–2007: slightly decreasing birth weight with increasing weight gain in pregnancy. J Perinat Med. 2009;37(4):374-379. [pmid: 19309253].
53 Talas BB, Altinkaya SO, Talas H, et al. Predictive factors and short-term fetal outcomes of breech presentation: a case-control study. Taiwan J Obstet Gynecol. Dec. 2008;47(4):402-407. [pmid: 19126505].
54 Tsukamoto H, Fukuoka H, Koyasu M, et al. Risk factors for small for gestational age. Pediatr Int. Dec. 2007;49(6):985-990. [pmid: 18045308].
55 Walker LO, Hoke MM, Brown A. Risk factors for excessive or inadequate gestational weight gain among Hispanic women in a U.S.-Mexico border state. J Obstet Gynecol Neonatal Nurs. Jul–Aug. 2009;38(4):418-429.
56 Wolff S, Legarth J, Vangsgaard K, et al. A randomized trial of the effects of dietary counseling on gestational weight gain and glucose metabolism in obese pregnant women. Int J Obes (Lond). Mar. 2008;32(3):495-501. [pmid: 18227847].
57 Wrotniak BH, Shults J, Butts S, et al. Gestational weight gain and risk of overweight in the offspring at age 7 y in a multicenter, multiethnic cohort study. Am J Clin Nutr. Jun. 2008;87(6):1818-1824. [pmid: 18541573].
58 Yogev Y, Langer O. Obesity and gestational diabetes. ACOG Clinical Review. 2008;13(5):7.
59 Denison FC, Price J, Graham C, et al. Maternal obesity, length of gestation, risk of postdates pregnancy and spontaneous onset of labour at term. BJOG. May. 2008;115(6):720-725. [pmid: 18410655].
60 Pergam SA, Wang CC, Gardella CM, et al. Pregnancy complications associated with hepatitis C: data from a 2003–2005 Washington state birth cohort. Am J Obstet Gynecol. Jul. 2008;199(1):38 e1-e9. [pmid: 18486089].
61 Asplund CA, Seehusen DA, Callahan TL, et al. Percentage change in antenatal body mass index as a predictor of neonatal macrosomia. Ann Fam Med. Nov–Dec. 2008;6(6):550-554. [pmid: 19001308].
62 Herring SJ, Oken E, Haines J, et al. Misperceived pre-pregnancy body weight status predicts excessive gestational weight gain: findings from a US cohort study. BMC Pregnancy Childbirth. 2008;8:54. [pmid: 19102729].
63 Catalano PM, Presley L, Minium J, et al. Fetuses of obese mothers develop insulin resistance in utero. Diabetes Care. Jun. 2009;32(6):1076-1080. [pmid: 19460915].
64 Lof M, Hilakivi-Clarke L, Sandin SS, et al. Dietary fat intake and gestational weight gain in relation to estradiol and progesterone plasma levels during pregnancy: a longitudinal study in Swedish women. BMC Womens Health. 2009;9:10. [pmid: 19402915].
65 Oken E, Kleinman KP, Belfort MB, et al. Associations of gestational weight gain with short-and longer-term maternal and child health outcomes. Am J Epidemiol. Jul. 15. 2009;170(2):173-180. [pmid: 19439579].
66 Paramsothy P, Lin YS, Kernic MA, et al. Interpregnancy weight gain and cesarean delivery risk in women with a history of gestational diabetes. Obstet Gynecol. Apr. 2009;113(4):817-823. [pmid: 19305325].
67 Rasmussen T, Stene LC, Samuelsen SO, et al. Maternal BMI before pregnancy, maternal weight gain during pregnancy, and risk of persistent positivity for multiple diabetes-associated autoantibodies in children with the high-risk HLA genotype: the MIDIA study. Diabetes Care. Oct. 2009;32(10):1904-1906. [pmid: 19592628].
68 Bodnar LM, Wisner KL, Moses-Kolko E, et al. Prepregnancy body mass index, gestational weight gain, and the likelihood of major depressive disorder during pregnancy. J Clin Psychiatry. Sep. 2009;70(9):1290-1296. [pmid: 19607761].
69 Viswanathan M, Siega-Riz AM, Moos MK, et al. Outcomes of maternal weight gain. Evid Rep Technol Assess (Full Rep). May. 2008;(168):1-223. [pmid: 18620471].
70 Eastman NJ, Jackson E. Weight relationships in pregnancy. I. The bearing of maternal weight gain and pre-pregnancy weight on birth weight in full term pregnancies. Obstet Gynecol Surv. Nov. 1968;23(11):1003-1025. [pmid: 5702412].
71 Abrams B. Prenatal weight gain and postpartum weight retention: a delicate balance. Am J Public Health. Aug. 1993;83(8):1082-1084. [pmid: 8342710].
72 Suitor CW. Maternal weight gain: a report of an expert work group (pdf full text). Rockville, MD. 1997.
73 Schieve LA, Cogswell ME, Scanlon KS. Trends in pregnancy weight gain within and outside ranges recommended by the Institute of Medicine in a WIC population. Matern Child Health J. Jun. 1998;2(2):111-116. [pmid: 10728266].
74 Lederman SA, Paxton A, Heymsfield SB, et al. Body fat and water changes during pregnancy in women with different body weight and weight gain. Obstet Gynecol. Oct. 1997;90(4 Pt 1):483-488. [pmid: 9380301].
75 Carmichael S, Abrams B, Selvin S. The pattern of maternal weight gain in women with good pregnancy outcomes. Am J Public Health. Dec. 1997;87(12):1984-1988. [pmid: 9431288].
76 Caulfield LE, Witter FR, Stoltzfus RJ. Determinants of gestational weight gain outside the recommended ranges among black and white women. Obstet Gynecol. May. 1996;87(5 Pt 1):760-766. [pmid: 8677082].
77 Pregnancy-related behaviors among migrant farm workers—four states, 1989–1993. MMWR Morb Mortal Wkly Rep. Apr. 4. 1997;46(13):283-286. [pmid: 9121420].
78 Hickey CA, McNeal SF, Menefee L, et al. Prenatal weight gain within upper and lower recommended ranges: effect on birth weight of black and white infants. Obstet Gynecol. Oct. 1997;90(4 Pt 1):489-494. [pmid: 9380302].
79 Siega-Riz AM, Adair LS, Hobel CJ. Institute of Medicine maternal weight gain recommendations and pregnancy outcome in a predominantly Hispanic population. Obstet Gynecol. Oct. 1994;84(4):565-573. [pmid: 8090394].
80 Siega-Riz AM, Hobel CJ. Predictors of poor maternal weight gain from baseline anthropometric, psychosocial, and demographic information in a Hispanic population. J Am Diet Assoc. Nov. 1997;97(11):1264-1268. [pmid: 9366864].
81 Dietz PM, Callaghan WM, Cogswell ME, et al. Combined effects of prepregnancy body mass index and weight gain during pregnancy on the risk of preterm delivery. Epidemiology. Mar. 2006;17(2):170-177. [pmid: 16477257].
82 Oken E, Taveras EM, Kleinman KP, et al. Gestational weight gain and child adiposity at age 3 years. Am J Obstet Gynecol. Apr. 2007;196(4):322 e1-e8. [pmid: 17403405].
83 DeVader SR, Neeley HL, Myles TD, et al. Evaluation of gestational weight gain guidelines for women with normal prepregnancy body mass index. Obstet Gynecol. Oct. 2007;110(4):745-751. [pmid: 17906004].
84 Stotland NE, Haas JS, Brawarsky P, et al. Body mass index, provider advice, and target gestational weight gain. Obstet Gynecol. Mar. 2005;105(3):633-638. [pmid: 15738036].
85 Olson CM, Strawderman MS. Modifiable behavioral factors in a biopsychosocial model predict inadequate and excessive gestational weight gain. J Am Diet Assoc. Jan. 2003;103(1):48-54. [pmid: 12525793].
86 Cogswell ME, Scanlon KS, Fein SB, et al. Medically advised, mother’s personal target, and actual weight gain during pregnancy. Obstet Gynecol. Oct. 1999;94(4):616-622. [pmid: 10511369].
87 Taffel SM, Keppel KG, Jones GK. Medical advice on maternal weight gain and actual weight gain. Results from the 1988 National Maternal and Infant Health Survey. Ann N Y Acad Sci. Mar. 15. 1993;678:293-305. [pmid: 8494272].
88 Brawarsky P, Stotland NE, Jackson RA, et al. Pre-pregnancy and pregnancy-related factors and the risk of excessive or inadequate gestational weight gain. Int J Gynaecol Obstet. Nov. 2005;91(2):125-131. [pmid: 16202415].
89 Hickey CA, Cliver SP, Goldenberg RL, et al. Relationship of psychosocial status to low prenatal weight gain among nonobese black and white women delivering at term. Obstet Gynecol. Aug. 1995;86(2):177-183. [pmid: 7617346].
90 Hickey CA. Sociocultural and behavioral influences on weight gain during pregnancy. Am J Clin Nutr. May. 2000;71(5 Suppl):1364S-1370S. [pmid: 10799414].
91 Walker LO, Kim M. Psychosocial thriving during late pregnancy: relationship to ethnicity, gestational weight gain, and birth weight. J Obstet Gynecol Neonatal Nurs. May–Jun. 2002;31(3):263-274.
92 Brunner Huber LR. Validity of self-reported height and weight in women of reproductive age. Matern Child Health J. Mar. 2007;11(2):137-144. [pmid: 17066316].
93 Gillum RF, Sempos CT. Ethnic variation in validity of classification of overweight and obesity using self-reported weight and height in American women and men: the Third National Health and Nutrition Examination Survey. Nutr J. 2005;4:27. [pmid: 16209706].