# Methods

The three phases of this project, including the update of the literature search from the 2008 report and the identification and prioritization of future research needs, are summarized in Figure 2. While we began the first two phases of the project at the same time, they were undertaken separately.

Figure 2 Identification and prioritization process diagram

Figure 2 summarizes the three phases of the current project, including the update of the literature search from the 2008 report and the identification and prioritization of future research needs. Under phase 1, gaps were identified from the Institute of Medicine report, the systematic evidence review, and other materials, and the 2008 report search strategies were recapitulated to update the literature. Phase 2 comprised three parts: inquiry and concept building, and two rounds of ranking and prioritization. Phase 3 consisted of a stakeholder conference call and ideal studies for highest priority items.

## Phase 1 Identifying Recently Completed and Ongoing Studies

Databases. We aimed to replicate the search executed in the 2008 report, from its end-date of October 2007 to January 2010. Our search included examination of results in four databases: PubMed MEDLINE, EMBASE, the Cumulative Index to Nursing and Allied Health Literature (CINAHL), and the Cochrane database (Tables 3–6). We also hand-searched the reference lists of relevant articles to identify additional citations for review.

Table 3 PubMed search strategies

Search # | Terms
#1 | Weight gain[mh]
#2 | Pregnancy[mh]
#3 | #1 AND #2
#4 | Gestational weight gain
#5 | #3 OR #4
#6 | (#3 OR #4) AND eng[la] AND humans[mh]
#7 | (“Outcome Assessment (Health Care)”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH] OR “Pregnancy Outcome”[MeSH] OR “Reproductive History”[MeSH] OR “birth outcomes” OR “infant health outcomes” OR “maternal health outcomes”) AND eng[la] AND humans[mh]
#8 | #6 AND #7 AND eng[la] AND humans[mh]
#9 | “counseling”[mh] OR “directive counseling”[mh]
#10 | #6 AND #8
#11 | “body weights and measures”[mh]
#12 | #6 AND #10
#13 | Anthropometry[mh]
#14 | #11 AND #12
#15 | #7 OR #9 OR #13
#16 | limit #14 to items added to PubMed from 10/03/2007 to present

Table 4 EMBASE search strategies

Search # | Terms
#1 | exp weight gain/
#2 | exp pregnancy/
#3 | #1 AND #2
#4 | exp pregnancy outcome/
#5 | exp pregnancy complication/
#6 | #4 OR #5
#7 | #3 AND #6
#8 | limit #7 to human and English language
#9 | morphometrics/or anthropometry/
#10 | #3 AND #9
#11 | limit #10 to human and English language
#12 | #8 OR #11
#13 | limit #12 to yr=“2007-Current”

Table 5 CINAHL search strategies

Search # | Terms
#1 | MH “Weight gain+” OR “weight gain”
#2 | MH “pregnancy+” OR pregnancy OR pregnant OR maternal
#3 | #1 AND #2
#4 | MH “pregnancy outcomes+” OR MH “pregnancy complications+” OR MH “infant, large for gestational age” OR MH “infant, low birthweight+” OR MH “infant, premature”
#5 | limit #3 AND #4 to English language, peer-reviewed journals and excluding MEDLINE records
#6 | MH “counseling+” OR counseling OR advice OR advise OR guidance
#7 | limit #3 AND #6 to English language, peer-reviewed journals and excluding MEDLINE records
#8 | MH “Body Weights and Measures+”
#9 | limit #3 AND #8 to English language, peer-reviewed journals and excluding MEDLINE records
#10 | #5 OR #7 OR #9
#11 | limit #10 to items published from 2007 to present

Table 6 Cochrane search strategies

Search # | Terms
#1 | (maternal weight gain OR gestational weight gain OR weight gain during pregnancy).mp.

Search terms. Controlled vocabulary terms served as the foundation of our search in each resource, complemented by additional keyword terms and phrases selected to represent each of the key concepts in the search. We also employed indexing terms when possible to exclude undesired publication types (e.g., reviews, case reports, letters, etc.) and articles published in languages other than English.

Article selection process. In order to properly update the search from the 2008 report we used the same inclusion and exclusion criteria, with a modification of publication date (Table 7). Once we identified articles through the electronic database searches and bibliographies we examined the abstracts of articles to determine the inclusion criteria set by the 2008 review. Two reviewers separately evaluated the abstracts for inclusion or exclusion, using an updated Abstract Review Form (Appendix C). If one reviewer concluded that the article was eligible based on the abstract, we retained it. For the full article review two reviewers read each article and decided whether it met the inclusion criteria, using the Full Text Inclusion/Exclusion Form (Appendix C).

Table 7 Inclusion/exclusion criteria for gestational weight gain

Category | Criteria
Study population | Women of any age with singleton pregnancies
Study settings and geography | KQ 1, KQ 2, KQ 4: Developed nations: United States, Canada, Western Europe, Japan, Australia, New Zealand KQ 3: United States KQ 5: All countries
Time period | October 2007 to January 2010
Publication languages | English only
Admissible evidence (study design and other criteria) | Admissible designs:; - Controlled trials (n ≥ 40), nonrandomized controlled trials (n ≥ 40), systematic reviews, meta-analyses, prospective trials with historical controls (n ≥ 40), prospective or retrospective observational cohort studies (n ≥ 40), and medium to large case series (n ≥ 100); Other criteria; - Original research studies must provide sufficient detail regarding methods and results to enable use and adjustment of the data and results.; - Relevant outcomes must be abstractable from data presented in the papers.; - Sample sizes must be appropriate for the study question addressed in the paper; single case reports or small case series (n < 100) are excluded.; - For KQ 1, 2, 3, and 4: prepregnancy body mass index (BMI) or weight must be accounted for in the relationship between maternal weight gain and outcome.; - Studies limited to women with preexisting health conditions only are excluded.

## Engaging Stakeholders, Researchers, Funders

The Vanderbilt Evidence-based Practice Center worked with the Scientific Resource Center to develop a group of stakeholder individuals and organizations with expertise and vested interest in the topic. We asked for the organizations to nominate potential stakeholders in four areas: advocacy, clinical practice, research, and research funding priorities. The initial list of potential organizations, developed by the Vanderbilt Evidence-based Practice Center, from which stakeholder nominations was solicited is in Table 8. We aimed for balanced representation across provider specialties, interest of advocacy organizations, those involved in making guidelines and recommendations, and in prioritizing use of research funds.

Table 8 Weight gain in pregnancy stakeholder sample organizations

Maternal Weight Gain Stakeholder Organizations/Affiliations
American Academy of Family Physicians
American Academy of Nurse Practitioners
American Academy of Pediatrics (Perinatology Section)
American Association for Diabetes Educators
American College of Nurse Practitioners
American College of Nurse-Midwives
American Congress of Obstetricians and Gynecologists
American Diabetes Association
American Dietetic Association
American Nurses Association
American Public Health Association
American Society for Nutrition
Association of Women’s Health, Obstetric and Neonatal Nurses
Centers for Disease Control and Prevention-Nutrition Branch
Childbirth Connection
Health Resources and Services Administration
International Food Information Council Foundation
March of Dimes
Midwives Alliance of North America
National Association of Nurse Practitioners in Women’s Health
National Eating Disorders Association
National Institute of Child Health and Human Development-Perinatology Research Branch
Maternal Weight Gain Stakeholder Organizations/Affiliations
Our Bodies, Ourselves
The American Pregnancy Association
The Obesity Society
Trust for America’s Health
World Health Organization

## Prioritizing Future Research

Phase 2: Prioritizing research. Our protocol for obtaining stakeholder input on research question prioritization was loosely based on the principles of the Delphi process, modified to maximize electronic communication and to streamline discussion. In short, we began by identifying a list of candidate research topics and initiating an iterative electronic process to refine and then rank the topic list. We then concluded the process with a teleconference that allowed personal interaction between the participants and discussion of the research priorities.

Initially, we conducted a detailed analysis (two readers and electronic key word searches within documents) of the 2008 review, and the IOM Guidelines searching for stated future research needs or identification of specific gaps. Our goal for this step was to clearly describe the state of the literature and form the starting point for the “snowball” list of all possible domains.

Review of the pilot protocol to gather stakeholder input was reviewed and approved by the Vanderbilt Institutional Review Board. Potential stakeholders were contacted by email, with a personal phone call followup as needed, to participate in the process. To maximize ability to engage stakeholders and to explore which approaches they preferred, we offered stakeholders three choices for participation in the very first phase of Inquiry and Concept Building (snowballing of ideas): online submission of information, individual phone conversations, or group conference call. The general consensus was to proceed with the “snowballing” process by means of electronic communication.

Step 1: Snowballing. Drawing on the 2008 report, the 2009 IOM report and other publications, we developed a list of 37 research questions for electronic review by the stakeholder panel. This initial list of candidate research questions was divided into five classes by the Vanderbilt Evidence-based Practice Center team: General Evidence Gaps, Interventions, Standardization Issues, Policy, and Measurement, which were used to seed the snowballing process with stakeholders. We invited the panel to submit comments regarding the initial list, including better ways to express research topics, ways to make the list broader and more comprehensive and to suggest topics we may have omitted. We intentionally did not ask the stakeholders to rank questions or to suggest ways to reduce the number of items at this “snowballing” point in the process, as we wanted to be as inclusive as possible, to ensure that the review panel would have a complete and relatively unbiased list of research topics from which to begin the prioritization process.

Step 2: Initial ranking. After “snowballing” the list of items we had a total of 50 research questions related to evidence gaps. We asked stakeholders to electronically rank these items from 0–10 in four domains: overall importance, clinical utility, feasibility, and potential to advance science. In this stage the lowest ranking responses were eliminated. They were considered to be low ranking if fewer than 30 percent of stakeholders scored the item as a 9 or 10 across the four domains.

After ranking research questions, stakeholders were also asked to prioritize candidate measures and outcomes arising from the research questions. Because questions included both a measure of exposure—in this case multiple candidate approaches to measuring maternal weight or weight gain—and an outcome, the number of combinations of exposures and outcomes would have resulted in a total number of questions that were impractical for ranking if all possible permutations were added to the list. Therefore we also sought to gain a sense of the perceived importance of focusing future research on specific measures of maternal weight gain; assigning “1” as the most important and “12” as the least important. The ranking scores were added together across respondents so that the measure with the highest score was identified as the least important. A similar process was used to rank the five broad categories of outcomes that encompassed all the outcomes proposed in the full list of items. They included: maternal antepartum outcomes, development of gestational diabetes, fetal outcomes, intrapartum outcomes, neonatal outcomes, maternal postpartum outcomes, infant health outcomes, and child health outcomes.

Step 3: Final ranking of reduced list of items. We then sent the reduced list of future research questions to the stakeholders and asked them to again rank them across the four domains of overall importance, clinical utility, feasibility, and potential to advance science. Responses to this second survey were then used to create a ranked list of the topics for discussion during a teleconference call. For this step in ranking research questions, the ranking scores were multiplied by the number of responses and these scores were added together so that the measure with the highest score was the most important. For example, if out of 5 participants 3 ranked the question as 5 out of 10 in importance and 2 ranked the question as 10 out of 10, that question would receive a score of (5*3) + (2*10) =35. These scores were then compared across questions and a final listing of top priority items prepared for review with the stakeholders.

## Determining Appropriate and Feasible Study Design

Phase 3. Optimal research designs to address top priority questions. In the final phase of this project, the stakeholder panel held a two and a half hour teleconference on the final ranking of priorities for future research in order to inform recommendations about the ideal study design(s) to address the highest priority items. A face-to-face meeting was initially planned but proved to be unworkable within the project timeline.

In advance of the meeting, participants were provided with the final overall rankings which included the five questions that ranked as highest priority by each domain as well as the summary results for the prioritization of the measures of maternal weight and weigh gain and categories of outcomes. All prior results, including rankings within classes of research questions (General Evidence Gaps, Interventions, Standardization Issues, and Measurement) and by overall importance, clinical utility, feasibility, and potential to advance science, were available to participants during the call.

The group discussed the utility and clarity of the causal framework, their impression of the final list and its comprehensiveness and discussed remaining gaps which they felt were overlooked in the process. However the primary agenda for the meeting was to recommend the most appropriate and feasible research designs to address the top priority items.

## Handling Conflicts of Interest

We obtained the standard AHRQ Conflict of Interest forms from all participants including our EPC faculty and staff. None of the identified stakeholders or EPC team members had a conflict judged to preclude participation in the process. Stated conflicts included the following:

- Funded research from agencies and foundations such as the NICHD, NHLBI, and the American Diabetes Association
- Employment with a professional organization
- Involvement with the adoption of 2009 IOM recommendations by the government (Canada)
- Membership on the board of a foundation related to obesity and maternal and child health research

During the snowballing and ranking process the participant stakeholders had no information about the identities of the other participants. Until the conclusion of each step they did not have access to scores and then only to the aggregate. Beginning the process with recruitment of additional items was intended to allow the scope of topics for future research to expand and to assure that a large number and range of potentially important topics were considered. Since the group elected to do their work electronically, individual persuasiveness or dominance of the conversation by particular topics did not have potential to sway the group opinion or the overall process.

At conclusion of the project, the preliminary draft of this report was also posted for public comment. We specifically solicited feedback about [what elements]. Public commentary was [characterize] and emphasized [what exactly]. The input has been incorporated in this final version of the report.