# Executive Summary

The Effective Health Care Program was initiated in 2005 to provide valid evidence about the comparative effectiveness of different medical interventions. The object is to help consumers, health care providers, and others in making informed choices among treatment alternatives. Through its Comparative Effectiveness Reviews, the program supports systematic appraisals of existing scientific evidence regarding treatments for high-priority health conditions. It also promotes and generates new scientific evidence by identifying gaps in existing scientific evidence and supporting new research. The program puts special emphasis on translating findings into a variety of useful formats for different stakeholders, including consumers.

The full report and this summary are available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.

## Background

This investigation of future research needs builds on work of the RTI–University of North Carolina at Chapel Hill Evidence-based Practice Center. Their team conducted the systematic evidence review on Outcomes of Maternal Weight Gain released in 2008. The rationale for the review cited specific trends in perinatal health with important public health implications as driving factors for conduct of the review:

- Since the 1990 Institute of Medicine (IOM) BMI guidelines on weight gain in pregnancy were published, data show that women in the United States are increasingly gaining more weight during pregnancy than recommended;1 including excess weight gain among overweight and obese women.2–4
- Overweight and obesity among women of childbearing age are rising5–8 as are levels among preschool children.9
- Adults tend to gain weight with age so that advancing maternal age contributes to higher prepregnancy body weight.
- Pregnancy complications associated with excess weight, such as gestational diabetes, large-for-gestational-age babies,10 and cesarean birth,11 are increasing in prevalence.

Parameters for the review were broad—findings were meant to be applicable to all pregnant women with singleton pregnancies. Notably, the typical dominant focus of systematic reviews on the effectiveness of interventions and comparisons of interventions was absent. This reflected the fact that the literature contained relatively few studies of interventions to support recommended weight gain that linked weight gain with outcomes. Rather, the review focused on whether evidence convincingly links weight gain or rate of gain to outcomes and evaluated whether the association was directly the result of weight gain and not indirectly the result of other factors closely related to weight gain, such as initial weight and nutritional content of the diet. The review team was interested in all outcomes, short- and long-term, and in all settings in which weight gain had been studied.

## Key Questions Addressed by 2008 Systematic Review

The 2008 AHRQ systematic review addressed the following Key Questions (KQs):

- Key Question 1. What is the evidence that either total weight gain or rate of weight gain during pregnancy is associated with (1) birth outcomes, (2) infant health outcomes, and (3) maternal health outcomes? Does any evidence suggest that either total weight gain or rate of weight gain is a causal factor in infant or maternal health outcomes?
- Key Question 2. What are the confounders and effect modifiers for the association between maternal weight gain (overall and patterns) and birth outcomes? Based on the findings in KQ 1, do these confounders and effect modifiers themselves contribute to antepartum or postpartum complications or to longer-term maternal and fetal complications, including development of adult obesity?
- Key Question 3. What is the evidence that weight gains above or below thresholds defined in the 1990 Institute of Medicine BMI Guidelines or weight loss in pregnancy contribute to antepartum or postpartum complications or longer-term maternal and fetal complications? How do these relationships vary by sociodemographic characteristics (i.e., race and age)?
- Key Question 4. What are the harms or benefits of offering the same weight gain recommendations to all pregnant women, irrespective of age and body weight considerations (e.g., pregravid weight, actual body weight at a particular time point, or optimal body weight)?
- Key Question 5. What are the anthropometric tools for determining adiposity and their appropriateness for the pregnancy state? What are the risks and benefits of measuring adiposity for (1) clinical management of weight gain during pregnancy and (2) evaluation of the relationship between weight gain and outcomes of pregnancy?

Examining these questions, the researchers concluded gestational weight gain is associated with some infant and maternal outcomes, including moderate evidence for an association of higher weight gain with increased risk of cesarean delivery, and for lower weight gain and increased risk of preterm birth, low birthweight, and small-for-gestational-age (SGA) infant. They noted strong evidence for high weight gain being associated with high birthweight, macrosomia, and large-for-gestational-age (LGA) infant. The studies reviewed provided strong evidence for the independent association of pregravid weight status amplifying the effect of gestational weight gain on outcomes. The systematic evidence review (SER) also concluded one weight gain recommendation for all women was not supported by the evidence. The report included a section on future research needs, which was the nidus of the list of research gaps identified and prioritized in this report.

## Methods

This project had three phases: (1) update of the literature search from the 2008 report; (2) identification and ranking of future research needs stated as research questions; and (3) recommendations of optimal study design to address those research questions judged to be top priority.

Phase 1: Literature scan. We aimed to replicate the search executed in the 2008 report, from its end-date of October 2007 to January 2010. Our search included four databases: PubMed MEDLINE, EMBASE, the Cumulative Index to Nursing and Allied Health Literature (CINAHL), and the Cochrane database. We also hand-searched reference lists of relevant articles to identify additional citations.

Once we identified articles we applied the inclusion criteria from the 2008 review. Two reviewers separately evaluated the abstracts. If one reviewer concluded the article was eligible we retained it. For the full article review two reviewers read each article and applied inclusion criteria. Critical information was abstracted to provide a snapshot of interim changes in the state of the literature. This included study design, country and setting of the research, specific interventions being evaluated, if interventions broadly defined as related to maternal weight or weight gain were included, and funding source.

Phase 2: Inquiry and concept building. Our protocol for obtaining stakeholder input on identification and prioritization of future research needs was loosely based on the principles of the Delphi process, modified to maximize electronic communication.12–13

To accommodate stakeholders and explore which approaches were preferred, we offered stakeholders three choices for participation in this phase: online, individual phone conversations, or group conference call. All participants selected to proceed by means of electronic communication (Web-based and e-mail). A total of 29 stakeholders representing academic research dietitians and epidemiologists, health care professional organizations, and national foundations and societies related to weight gain and/or maternal health participated in one or more of the stages of ranking and prioritization.

As a first step, we conducted an analysis of the 2008 review, the 2009 IOM BMI Guidelines, and other publications for stated future research needs and knowledge gaps. Our goal for this step was to clearly describe the content of the literature and provide a starting list from which to grow a “snowball” list of all questions believed to be important by stakeholders.

The nidus for the snowball was a list of 37 research questions grouped into five classes: General Evidence Gaps, Targets for Intervention, Standardization Issues, Policy, and Measurement. We invited the stakeholders to submit revisions and additions. At this phase, we intentionally did not ask the stakeholders to rank questions but rather to expand the list of items under consideration. This allowed unhindered entry of concepts onto the list.

The second step was an initial ranking of the 50 items resulting from snowballing. Stakeholders electronically ranked all items from 0 (low) to 10 (high) in four domains: overall importance, clinical utility, feasibility, and potential to advance science. At conclusion of this stage the lowest ranking responses were eliminated. An item was considered to be low ranking if fewer than 30 percent of stakeholders scored it as 9 or 10 across the four domains. We also included a separate set of items to prioritize among candidate measures and outcomes.

In the final step we provided the reduced list of future research questions to the stakeholders and asked them to again rank them across the four domains of overall importance, clinical utility, feasibility, and potential to advance science. Responses to this second survey were then used to create a final ranked list of research questions, measurement approaches, and outcomes.

Phase 3: Optimal research designs to address top priority questions. We held a concluding two and a half–hour conference call to consider what research approaches were most appropriate and feasible to address the identified questions and reflected back the summary to the group.

## Results

### Phase 1 Literature Scan

We identified 55 new relevant publications14–68 representing 52 populations: three were randomized controlled trials (RCTs); three, systematic reviews and meta-analyses; and 46, observational studies. They were most frequently retrospective cohorts (n = 24) conducted in the United States (n = 27) with participants recruited most often from the community (n = 20). Funding for most of the current studies was from national sources, including various components of the National Institutes of Health in the United States and the Ministry of Health, Labor, and Welfare in Japan. The focus of all 52 studies was to determine the influence of prepregnancy weight or BMI. The measures of prepregnancy weight/BMI varied from measurements taken at the first prenatal visit to self-report of prepregnancy measurements. Risk of cesarean delivery was the focus for approximately one-fourth of all of the included studies, while nearly two-thirds reported infant and child health outcomes, including Apgar scores and birthweight. Three were small clinical trials of dietary counseling, two combined with physical activity.16,35,56 Each found a higher portion of women advised about means to achieve target weight gain were more likely to do so that those in comparison groups. None of these studies were judged to definitively address one or more research gaps or to substantively change the framework or intended process for developing and prioritizing future research needs.

### Phase 2 Inquiry and Concept Building

Step 1. During the snowballing process the stakeholders increased the list from 37 initial questions to 50. The 50 research questions captured both specific research methods that need to be used and knowledge gaps that must be filled to inform and ultimately improve clinical care. The research questions also encompassed a wide range of specific approaches to measurement of maternal weight, weight gain, and body habitus, as well as a range of specific outcomes.

Step 2. The full list of 50 items, 12 measurement approaches, and eight outcome categories was compiled and presented to the stakeholders for assigning priority scores as described in methods. Eliminating those items that were low scoring resulted in 27 remaining research questions. All questions related to issues of policy were eliminated at this stage. In addition, among the 12 measurement standards and eight outcomes, the lowest ranking one-third of each list was eliminated resulting in eight and five items respectively progressing into the next round.

Step 3. In the final stage of ranking to establish priorities, participants were asked to score the 27 research questions as well as the remaining eight candidate measures and five outcomes. We present the final priority ranking for measures and outcomes first since this ranking carries forward into the interpretation of the research questions prioritized.

“Total weight gain from prepregnancy to end of pregnancy” was considered the highest priority measure of maternal weight gain for future research followed by “prepregnancy baseline weight/BMI” and “change in body/body fat composition.” The final prioritization of outcomes ranked “maternal postpartum” and “child health” outcomes as the most important outcomes for future research on maternal weight gain.

The full report presents the ranking scores and final prioritization of the research questions within the classes of items, including scores for each of the four domains (overall importance, clinical importance, feasibility of research, and potential to advance the science).

Based on scores only for the domain “overall importance” the top ranking items were:

1. What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes?
2. Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?
3. Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]?
4. What factors confound the relationship between [weight gain in pregnancy] and [outcomes]?
5. What physiologic or clinical factors modify the relationship between [weight gain in pregnancy] and [outcomes]?

Our process considered the final composite prioritization of all of the research questions for future research to be based on averaging the scores across all four domains. That approach to ranking resulted in the following list of the top five from highest priority to lower priority:

1. Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?
2. Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]?
3. What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes?
4. Does gestational weight gain above targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?
5. Does gestational weight gain below targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?

### Phase 3 Optimal Research Designs To Address Top Priority Question

Stakeholders were reluctant to dictate a specific form of study design because many research areas are at a nascent stage that might benefit from a multiplicity of approaches. They indicated that it would be helpful to modify the causal framework to reflect that social, cultural, and environmental factors have an encompassing influence, not acting as the initial framework visually suggest primarily through influence on diet and energy expenditure. With that broad view in mind they expressed some dismay that the process did not ultimately provide top-ranking questions to be addressed by interventions, especially randomized trials, or by community-based research or hybrid approaches, such as fundamentally changing prenatal care and resources in communities.

Members noted that though it was possible to add items the process was unidirectional after the first step. They considered whether this resulted in inadvertently missing concepts that occurred to participants after the snowballing stage. When specifically queried about the two prioritization lists presented above, they did not feel the process had identified questions that were not of pressing concern or would not be among the crucial next questions to be answered in order to accomplish the goals of advancing the science and informing clinical care. On reflection, the group also noted that the emphasis on methodologic and analytic priorities is warranted, as doubts about the importance of maternal weight gain will persist until the science examining causal contributions to outcomes is more highly developed. They expressed that once such associations are more definitively understood the field would be better prepared to direct interventions properly toward changing the desired outcomes.

Concepts presented as next steps included:

- Developing consensus about standards for methods of collecting prepregnancy weight and height as well as other body composition and anthropometric measures.
- Maximizing use of existing data collection infrastructure (new birth certificate formats, Behavioral Risk Factor Surveillance System [BRFSS], and the Pregnancy Risk Assessment Monitoring System [PRAMS]) to develop national surveillance studies with large sample size among representative populations.
- Using current Women, Infants, and Children (WIC) infrastructure to conduct postpartum followup to include weighing pregnant and nonpregnant women consistently to allow for accurate baseline data for any subsequent pregnancies.
- Conducting national surveys, with possible inclusion of questions on BRFSS instruments, in order to determine knowledge and attitudes among women about weight gain and their experiences in care.
- Conducting similar evaluations of the knowledge, attitudes, and perceived barriers of providers that inhibit addressing maternal weight and weight gain.
- Launching intervention studies that include efforts to change the physical environment, including community-based interventions (e.g., increasing access to gyms and community centers in neighborhoods where it is not safe to exercise outside by distributing coupons/incentives to facilities).
- Coupling community-based interventions with individual-level interventions such as behavioral counseling and nutrition education or innovative means of prenatal care delivery, such as Centering Pregnancy (group prenatal care).
- Designing randomized controlled trials of promising interventions with large enough scope to make the causal relationship between weight gains above guideline thresholds and poor outcomes (maternal and child) explicitly testable.
- Collecting longer-term outcomes, such as child health and development data and study of maternal weight trajectories between and after pregnancies with more rigorous measures than those available to date.
- Strategizing means to assure a focus on maternal weight gain measures in upcoming national studies including the National Children’s Study.

## Discussion and Conclusions

Our first phase examined progression of the literature. In the 27 month interval between October 2007 and January 2010, three randomized clinical trials, including a total of 386 women, were published.16,35,56 In aggregate the results support prior findings that weight gain can be modified by dietary and lifestyle counseling interventions. None of the studies were large enough to adequately assess outcomes and did not contribute sufficient numbers to change aggregate knowledge about anticipated influence on outcomes among women who do or do not achieve target weight gains in pregnancy. No gap identified in the evidence review on maternal weight gain, the IOM proceedings, or the stakeholder discussions as part of this process was filled by a publication or changes in the body of evidence during the interim.

Across publications, stakeholder calls, and survey item development and responses, there was a strikingly consistent level of attention to the need (1) for greater uniformity in measures by means other than self-report, (2) for research that would open a vista on the biological mechanisms at work at a causal level, (3) for statistical analyses that explicitly address the joint contributions of multiple causal factors, and (4) for greater breadth and depth in outcomes assessed. Those engaged in this future research prioritization process indicated in both rankings and discussions that they favored operational definitions (such as research measurement of prepregnancy weight and height), approaches to data and analysis (encompassing baseline weight, caloric intake, nutrient content, physical activity, and weight gain patterns) and outcomes (such as child health and obesity and maternal life course weight trajectory) that can broadly be described as more rigorous than those that dominate the current literature.

In highly ranking both an explicit question about effect modification and another about confounding, this process reveals a level of scientific equipoise about causal influences that matches the large number of basic gaps identified in the literature and discussed in email and the call. Though we did not have a formal method for capturing impression about why this level of rigor was not yet commonly achieved, experts identified the need for greater funding resources and the challenges of long-term followup as barriers to accomplishing more definitive research.

Throughout the phases, the stakeholder group indicated a desire for more definitive understanding of how the many factors (such as those indicated in the causal pathway) work in concert to determine outcomes. They conveyed a level of concern that premature focus on interventions with a particular target, such as total weight gain, without attention to other factors, such as nutrient intake, could fail to improve the desired outcomes. Some participants reported frank doubts about whether the causal links are sufficiently formed to guide intervention solely for the sake of improving reproductive outcomes. However, a majority endorsed that in the United States cultural context of sedentary lifestyles, rising proportions of the population overweight or obese, and many with poor-quality diets, it is not inappropriate to simultaneously study interventions while studying causal factors. Intervention settings that attracted discussion ranged from conventional clinically anchored approaches to passionate advocacy for programs that seek to make more fundamental changes in how women think about weight and weight gain and how communities can be changed to promote healthy lifestyles.

This multiphase process for enumerating, multiplying, and prioritizing research questions to advance research in the area of maternal weight gain and pregnancy outcomes resulted in an actionable list of research topics to fill specific knowledge gaps that was endorsed by multidisciplinary experts. Inherent variation in how respondents valued items allowed selection of cut-offs to trim lists at each phase of prioritization. When the items were re-presented on shortened lists, constraining the scope, variation in prioritization persisted that made a final round of ranking desirable in solidifying recommendations for future research.

Stakeholders proposed ways to further extend the reach of the process to include greater scope in the candidate ideas via adding an early opportunity to create synergy in discussion and to actively encourage the “snowballing process.” However at conclusion, they were not dissatisfied with the prioritized topics. The core message of increased rigor as a necessity may be valuable for both endorsing streams of research considered descriptive, methodologic, and quantitatively focused—namely working out the nature of causal relationships—and for drawing the attention of investigators and funders to the importance of more demanding, larger, longer, prospective and intervention studies.

While the group was inspired to map the identified research priorities to study approaches, they were reluctant to specify a single, correct next step. They expressed confidence in the collective energy and creativity of the scientific community, suggesting that agencies and organizations seeking to advance research in this area solicit and amply fund investigator-initiated research rather than prespecifying study designs to answer high priority questions. Likewise there was confidence that robust expertise and appropriate study populations are available to realize answers to the prioritized questions quickly in order to bring practical tools and new knowledge to advancing the care of women and their children.