# Discussion and Conclusions

Our first phase examined progression of the literature in the time from the 2008 evidence review. In the 27 month interval, three randomized clinical trials, including a total of 386 women, were published.16,35,56 Each aimed to assist women in achieving target weight gains appropriate for their self-reported baseline BMI. Each included a component of individualized dietary counseling with advice about caloric intake and dietary composition. Two added targets for physical activity.16,35 All found that intervention helped some women stay within targets for weight gain. The largest study, in Australia, included women across the spectrum from underweight to obese. They found that underweight and overweight women benefited from the intervention while normal weight and obese women in the intervention arm were no more likely to be in the target than those in the comparison group. In aggregate the findings support prior findings that weight gain can be modified by dietary and lifestyle counseling interventions. None of the studies were large enough to adequately assess fetal, neonatal, or maternal outcomes and do not contribute sufficient numbers to change aggregate knowledge about anticipated influence on outcomes among women who do or do not achieve target weight gains in pregnancy.

Many of the new studies identified rely on administrative or survey samples that do not acquire physical measurement of weight or weight change, such as surveys of post-partum women and birth certificate analyses. No literature in the intervening period makes substantive, novel contributions to achieving targets of measured changes in maternal weight or assessment of large prospectively collected data that allows disentanglement of the many causal factors that may confound or modify effects of weight gain on outcomes.

No gap identified in the evidence review on maternal weight gain, the IOM proceedings, or the stakeholder discussions as part of this process to prioritize questions for future research was filled by changes in the body of evidence during the interim. This suggests that existing evidence reviews may serve as a profitable starting point for identifying a nidus of future research questions to jump start considerations of expert panels charged with prioritizing future research needs.

Across publications, stakeholder calls, and survey item development and responses, there was a strikingly consistent level of attention to the need for: (1) greater uniformity in measures, (2) research that would open a vista on the biological mechanisms at work at a causal level, (3) statistical analyses that explicitly address the joint contributions of multiple causal factors, and (4) greater breadth and depth in outcomes assessed. Those engaged in this future research prioritization process indicated in both rankings and discussions that they favored operational definitions (such as research measurement of prepregnancy weight and height), approaches to data and analysis (encompassing baseline weight, caloric intake, nutrient content, physical activity, and weight gain patterns) and outcomes (such as child health and obesity and maternal lifecourse weight trajectory) that can broadly be described as more rigorous than those which dominate the current literature.

The first two research questions in the final priority ranking of the five top research questions reflect this inclination to employ the “gold standard” of prepregnancy BMI or weight in analyses that address whether baseline characteristics or weight gained during pregnancy operate jointly or independently to influence outcomes:

- Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?
- Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]?
- In highly ranking both an explicit question about effect modification and another about confounding, this process reveals a level of scientific equipoise about causal influences that matches the large number of basic gaps discussed in calls. Though we did not have a formal method for capturing stakeholder impression about why this level of rigor was not yet commonly achieved, discussion often identified the need for greater funding resources and challenges of long-term followup as barriers to accomplishing more definitive research.

Because there were an exceptionally large number of permutations of proposed measures of weight and weight gain and specific outcomes, we engaged the stakeholders in prioritizing measures of weight and weight gain and outcomes separately. The reduced list of priority measures from higher to lower ranking was:

1. Total weight gain from prepregnancy to end of pregnancy
2. Prepregnancy baseline weight/BMI
3. Change in body/body fat composition
4. Pattern of weight gain across pregnancy as a statistical trend line or function
5. Total weight gain from first trimester to end of pregnancy
6. Pattern of weight gain across pregnancy
7. Rate of weight gain
8. Change in BMI from prepregnancy to end of pregnancy

The reduced list of prioritized outcomes was:

1. Maternal postpartum outcomes
2. Child health outcomes
3. Infant health outcomes
4. Development of gestational diabetes
5. Fetal outcomes

If there was complete internal consistency within ranking the top priority research question would link the top measure and the top outcome. In other words, “How does total weight gain from prepregnancy to end of pregnancy influence maternal postpartum outcomes?” would have surfaced among the final prioritized questions. However it did not explicitly appear in this form. After the first two items about effect modification and confounding, the third highest priority research question was based on weight gain and focused on infant and child health outcomes, not maternal outcomes:

“What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes?”

Maternal outcomes were subsumed in the last two of the final five items that received the highest priority rankings which included interest in multiple outcome categories:

- Does gestational weight gain above targets defined in 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum, and longer-term maternal and infant complications)?
- Does gestational weight gain below targets defined in 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum, and longer-term maternal and infant complications)?

Across the four major domains queried (overall importance, clinical utility, feasibility of the research, and potential to advance the science), there was a high level of consistency in the type of questions that ranked among those with high priority.

In discussion throughout the phases, the stakeholder group indicated a desire for more definitive understanding of how the many factors (such as those indicated in the causal pathway) work in concert to determine outcomes. They conveyed a level of concern that premature focus on intervening with a particular target like total weight gain without attention to other factors such as nutrient intake could fail to improve the desired outcomes. Some participants reported frank doubts about whether the causal links are sufficiently formed to guide intervention solely for the sake of improving reproductive outcomes. However, a majority seemed to endorse that in the U.S. cultural context of sedentary lifestyles, rising proportions of the population overweight or obese, and many with poor quality diets, it was not inappropriate to simultaneously study interventions while studying causal factors. Intervention settings that attracted discussion ranged from conventional clinically anchored approaches to passionate advocacy for programs that seek to make more fundamental changes whether it is in how women think about weight and weight gain in pregnancy and well-being or how communities can be changed to promote healthy lifestyles. Likewise there was interest in understanding more about the knowledge and attitudes of care providers and in means to disseminate recommendations.

Stakeholders noted they hoped that the funneling process used to reduce the priorities list did not have the unintended effect of suggesting that qualitative studies, investigations heavily using biomarkers, studies of genetic influences, intervention trials, and community-based research be dismissed. Rather they emphasized the importance of timely and coordinated answers to the core gaps in measurement and causal links as having exceptionally high value for informing all future research.

In general stakeholders reported the future research prioritization process was worthwhile. However, there was an impression both within the EPC team and the SER group that the process could have benefitted from:

- In-person discussion or at minimum teleconferencing both early and later in the process
- Means to avoid a “one-way street” in which items could be added only at the beginning and were trimmed without opportunity to introduce late-breaking ideas or concepts
- Decreasing the number of questions and options given during the ranking and prioritization portions of the process
- Less emphasis on selection of a specific study design to accomplish answers to priority items (believing that investigators will bring many valid approaches to addressing the questions)

When specifically queried if they believed the process concluded with research questions prioritized that are not of central importance across the domains, there was no concern expressed that items were included that should not be. Among the participants available for the wrap-up call, there was agreement that answer to the proposed priority research questions would make pivotal contributions towards understanding the results of maternal weight gain, caring for pregnant women, and honing new investigative tools. They would urge funders and policy makers to support enhanced funding and opportunities to focus on these gaps in knowledge.

## Conclusions

This multiphase process for enumerating, multiplying, and prioritizing research questions to advance research in the area of outcomes of maternal weight gain in pregnancy resulted in an actionable list of research topics to fill specific knowledge gaps. The results of prioritization, including these top five items, were endorsed by multidisciplinary experts:

1. Does prepregnancy BMI or prepregnancy weight modify the relationship between [weight gain in pregnancy] and [outcomes]?
2. Does prepregnancy BMI or prepregnancy weight confound the relationship between [weight gain in pregnancy] and [outcomes]?
3. What is the effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes?
4. Does gestational weight gain above targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?
5. Does gestational weight gain below targets defined in the 2009 IOM weight gain guidelines contribute to complications (including antepartum, postpartum longer-term maternal and infant complications)?

Inherent variation in how respondents valued items did allow selection of cut-offs to trim lists at each phase of prioritization. When the items were re-presented on shortened lists, constraining the scope, variation in prioritization persisted that made a final round of ranking desirable in solidifying recommendations for future research.

The expert stakeholders proposed ways to further extend the reach of the process to include greater scope in the candidate ideas by adding an early teleconference to create synergy in discussion and to actively encourage input in the “snowballing process”. However at conclusion, they were not dissatisfied with the prioritized topics. The core message of increased rigor as a necessity is valuable for both endorsing streams of research considered descriptive, methodologic, and quantitatively focused—namely working out the nature of causal relationships—and for drawing the attention of investigators and funders to the importance of more demanding, larger, and longer prospective and intervention studies.

While the group was inspired to map the identified research priorities to specific study approaches, they were reluctant to specify a single, correct next step. Confidence in the collective energy and creativity of the scientific endeavor, suggested that agencies and organizations seeking to advance research in this area would do best to solicit and amply fund research concepts that are responsive to the needs and to select those ideas that come forward as the most innovative and sophisticated means to support next steps. Likewise there was confidence that robust expertise and appropriate study populations are available to realize answers to the prioritized answer in a rapid timescale in order to bring practical tools and new knowledge to advancing the care of women and their infants.