# Background

## 2008 AHRQ Systematic Review of Outcomes of Maternal Weight Gain

This examination of future research needs builds on work of the RTI-University of North Carolina at Chapel Hill Evidence-based Practice Center. Their team conducted the systematic evidence review on Outcomes of Maternal Weight Gain released in 2008.^69^ The rationale for the review cited specific trends in perinatal health with important public health implications as driving factors for conduct of the review:

- Since the 1990 IOM guidelines on weight gain in pregnancy, women in the United States are increasingly gaining more weight during pregnancy than recommended;1 including excess weight gain among women who were overweight and obese before pregnancy.2–4
- Overweight and obesity among women of childbearing age are rising5–8 as are the levels among preschool children.9
- Adults tend to gain weight with age so that advancing maternal age contributes to higher prepregnancy body weight.
- Pregnancy complications associated with excess weight such as gestational diabetes, large-for-gestational-age babies,10 and cesarean birth11 are increasing.

Ideal weight gain during pregnancy has long been debated. Gestational weight gain includes the products of conception, the fetus and placenta, as well as increases in maternal fat stores, plasma volume, and uterine and breast tissue. Because pregnancy is the only common clinical situation in which the care provider has at least two patients—the mother and the fetus(es)—balancing the amount of weight gain needed to optimize the growth of babies without jeopardizing the health of mothers in either the short or the long term is essential.

In the 1930s, the recommendation to all pregnant women, irrespective of pregravid weight status, was 6.8 kg (about 15 pounds). This recommendation to restrict weight gain to decrease risk of pregnancy complications continued until 1970. It stemmed largely from the observation that increased maternal weight gain was related to higher birthweights.70 In 1970, however, the IOM determined that restriction of weight gain was likely to be harmful with respect to restricting birthweight; subsequently, formal weight gain recommendations were eased from less than 20 pounds throughout pregnancy to a range of 20 to 27 pounds.71

Over the next two decades, accumulating research suggested that one guideline was unlikely to suit all women and their fetuses. This recognition led an IOM committee to issue guidance to providers and to the public that was based on a woman’s pregravid weight.1 The 1990 IOM recommendations (Table 1) were weight gains of (1) 28 to 40 pounds for women with low body mass index (BMI), defined as < 19.8; (2) 25 to 35 pounds for women with normal BMI (19.8–26); and (3) 15 to 25 pounds for women with high BMI (> 26.0–29.0). Further, the recommendations included a weight gain of at least 15 pounds for obese women (BMI > 29), weight gain in the upper end of the recommended range for adolescents and black women, and weight gain in the lower end of the recommended range for women of shorter stature (< 157 centimeters [cm] or 62 inches). These recommendations were the first to account for pregravid weight status and to encourage obese women to gain weight during pregnancy, citing the nutritional needs of the fetus.

Table 1 IOM 1990 recommendations for weight gain during pregnancy by prepregnancy BMI

Prepregnancy BMI | BMI (kg/m^2^) | Total Weight Gain Range (lbs) | Rates of Weight Gain 2nd and 3rd Trimester (Mean Range in lbs/wk)
Underweight | <19.8 | 28–40 | 1 (1–1.3)
Normal weight | 19.8–26 | 25–35 | 1 (0.8–1)
Overweight | >26–29 | 15–25 | 0.6 (0.5–0.7)
Obese (all classes) | >29.0 | 15 | 0.5 (0.4–0.6)

The IOM also addressed patterns of weight gain by providing guidance on the ideal amount to be gained in the first trimester and rates of weight gain in the second and third trimesters. These recommendations tended to focus on the prevention of low birth-weight deliveries rather than the impact on maternal obesity and related health outcomes.

In 1996, an expert panel assembled by the Maternal and Child Health Bureau of the US Health Resources and Services Administration reexamined these recommendations. At the time, the panel decided that revisions were unnecessary. They found, however, that the evidence to date suggested that the recommendations for higher weight gains by black women and adolescents and lower weight gains for women of shorter stature were not well supported; they concluded that these subpopulations should be advised to stay within the IOM’s recommended weight range specific for their pregravid BMI.72

Since the 1990 IOM recommendations, several studies documented the low proportion of women meeting the guidelines. In a 1998 study of more than 120,000 women, 34 percent gained weight within the recommended ranges.73 The proportion of women gaining more than the recommended range increased over the time span 1990 to 1996 from 42 percent to 44 percent.73 The proportion of women gaining less than recommended remained relatively stable (23 percent to 22 percent). Other studies reporting on various subpopulations since the 1990 report also found that 30 to 40 percent of women gained weight within the recommended ranges.4,74–83 Although the IOM recommendations had been in place for almost two decades, between 35 percent and 60 percent of pregnant women reported receiving no advice from their providers about appropriate pregnancy weight gain.84–85 Pregnant women who reported being advised about the appropriate amount of weight to gain during pregnancy were more likely to gain within the recommended range than women who did not receive such advice.86–87 This link rests on a handful of studies, most conducted before or soon after the 1990 IOM guidelines.84,86–87

Persistent non-adherence to weight gain guidelines and wide variability in the amount of weight gained during pregnancy has served as the impetus for much research on predictors of gestational weight gain. This body of work suggests a multifactorial model is required.85,88–89 The bulk of research notes the importance of pregravid weight status, parity, height, race or ethnicity, age, age at menarche, physical activity, and psychosocial stress in influencing weight gain.85,88–91 Although such investigations are important, even more basic is an understanding of the short- and long-term benefits and risks of gestational weight gain for the mother, the fetus, and the child. The 2008 AHRQ SER was undertaken to fully explore what had been learned about the impact of gestational weight gain since the 1990 IOM recommendations. The parameters for the review were broad—the target population of interest for whom the findings were meant to be applicable was all pregnant women with singleton gestations. Notably, the common dominant focus of systematic reviews on the effectiveness of interventions and comparisons of interventions was absent. This reflected the fact that the literature contained relatively few studies focused on interventions to support recommended weight gain. The review took a more fundamental approach to determining whether there was evidence to convincingly link weight gain or rate of gain to outcomes and to assure that the association was direct and not indirectly the result of other factors that are closely related to weight gain like initial weight and nutritional content of the diet. The review team was interested in all outcomes, short- and long-term, and in all settings in which weight gain had been studied.

## Key Questions Addressed by 2008 AHRQ Review

Key Questions (KQs) addressed by the 2008 AHRQ systematic review were:

- Key Question 1. What is the evidence that either total weight gain or rate of weight gain during pregnancy is associated with (1) birth outcomes, (2) infant health outcomes, and (3) maternal health outcomes? Does any evidence suggest that either total weight gain or rate of weight gain is a causal factor in infant or maternal health outcomes?
- Key Question 2. What are the confounders and effect modifiers for the association between maternal weight gain (overall and patterns) and birth outcomes? Based on the findings in KQ 1, do these confounders and effect modifiers themselves contribute to antepartum or postpartum complications or to longer-term maternal and fetal complications, including development of adult obesity?
- Key Question 3. What is the evidence that weight gains above or below thresholds defined in the 1990 Institute of Medicine BMI Guidelines or weight loss in pregnancy contribute to antepartum or postpartum complications or longer-term maternal and fetal complications? How do these relationships vary by sociodemographic characteristics (i.e., race and age)?
- Key Question 4. What are the harms or benefits of offering the same weight gain recommendations to all pregnant women, irrespective of age and body weight considerations (e.g., pregravid weight, actual body weight at a particular time point, or optimal body weight)?
- Key Question 5. What are the anthropometric tools for determining adiposity and their appropriateness for the pregnancy state? What are the risks and benefits of measuring adiposity for (1) clinical management of weight gain during pregnancy and (2) evaluation of the relationship between weight gain and outcomes of pregnancy?

Examining these questions, the authors concluded gestational weight gain is associated with some infant and maternal outcomes, including moderate evidence for an association of higher weight gain and with increased risk of cesarean delivery, and for lower weight gain and increased risk of preterm birth, low birthweight, and small-for-gestational-age (SGA). They noted strong evidence for high weight gain being associated with high birthweight, macrosomia, and large-for-gestational-age (LGA). The studies reviewed provided strong evidence for the independent association of pregravid weight status amplifying the effect of gestational weight gain on outcomes. The SER also concluded one weight gain recommendation for all women was not supported by the evidence.

## Change in National Guidelines for Maternal Weight Gain

During the timeframe of the AHRQ report, the IOM convened the Committee to Reexamine the IOM Pregnancy Weight Guidelines. In 2009 they published Weight Gain During Pregnancy: Reexamining the Guidelines.1 This report outlined the need to reexamine the 1990 guidelines given the changing population of American women giving birth (older, more diverse, more likely to be overweight/obese). The Committee focused primarily on the importance of the woman’s weight at the start of pregnancy and the increased risk of chronic disease with overweight status and obesity. The new guidelines are based on the measure of body mass index and the categories developed by the World Health Organization (WHO) and implemented by National Heart, Lung, and Blood Institute (NHLBI). The IOM highlights that the new recommendations (Table 2) differ from the previous ones in that they are based in the WHO BMI categories and include a more restrictive range of weight gain for obese women. In contrast to the earlier guidance, women of shorter stature and racial and ethnic groups are advised to follow guidelines set for the whole population depending on their BMI category.

Table 2 IOM 2009 recommendations for weight gain during pregnancy by prepregnancy BMI

Prepregnancy BMI | BMI (kg/m^2^) | Total Weight Gain Range (lbs) | Rates of Weight Gain 2nd and 3rd Trimester (Mean Range in lbs/wk)
Underweight | <18.5 | 28–40 | 1 (1–1.3)
Normal weight | 18.5–24.9 | 25–35 | 1 (0.8–1)
Overweight | 25.0–29.9 | 15–25 | 0.6 (0.5–0.7)
Obese (all classes) | ≥30.0 | 11–20 | 0.5 (0.4–0.6)

The 2009 IOM recommendations differed from the 1990 IOM recommendations by adjusting the BMI ranges to match the WHO definitions, by allowing for as little as 11 pounds weight gain in women with obese prepregnant weight, and by eliminating special considerations other than prepregnant BMI. The IOM process also recognized that the 2008 AHRQ systematic review served as a stimulus for identifying current gaps in knowledge and critical future research.

## Research Gaps Identified in Prior Work

The AHRQ 2008 review included attention to defining critical topics for future research. The review team identified the limitations of the evidence and research gaps in two broad areas: (1) overall need for studies and (2) methodologic challenges to existing studies that limited the EPC’s ability to draw conclusions. For example, to understand fully the impact of gestational weight gain on short- and long-term outcomes for women and their offspring would require that researchers use consistent definitions of weight gain during pregnancy, improve standardization of methods and timing of weight measures, better address confounders in their analyses, improve study designs and statistical models, and conduct studies with longer followup. As a matter of course, the SER was not able to address the newest 2009 IOM recommendations (Table 2), which raise additional questions.

The analytic framework for the 2008 report, adopted from the 1990 IOM report, has been modified here to illustrate research gaps that remained and were identified in the report and our review of literature published since 2008 (Figure 1). This analytic framework indicates gaps identified during the 2008 review and our horizon scan of the literature through the use of dashed circles and squares. The dashed circles represent gaps linked to specific stages in the framework. However, there were several general research needs that could not be linked to particular components of the pathway as they likely have broad influence on both weight gain and outcomes. They are included in the dashed square in the bottom right of the diagram. The primary linkages are indicated in the boxes along the center line where individual maternal factors and society meet. In this annotated framework, key questions are not indicated. Each of the domains listed among individual and social/built/natural and life-stage environment, such as media, environmental toxicants, access to healthy foods, and family status, has been shown to influence diet composition, energy intake, energy expenditure, and energy balance.

Figure 1 Annotated analytic framework indicating identified gaps in methods and content

Figure 1 depicts research gaps identified in an analytic framework that was developed to understand the influence of societal and individual maternal factors on weight gain during pregnancy. Text boxes and arrows illustrate the factors, and the research gaps are described within seven dashed circles, with arrows pointing to the related factors. Twelve general research needs not related to specific factors but having broad influence on weight gain and outcomes are listed in a dashed box in the bottom right corner. The figure contains three boxes along the center line where individual maternal factors and society meet. The center box contains the heading “pregnant woman,” with these bullet-point terms listed: fetus, placenta, amniotic fluid, and in one bullet point, increased maternal fat stores, uterine weight, breast tissue, and plasma volume. Pathways of boxes and arrows point to this box from the left, top, and bottom, illustrating that the individual maternal and societal factors affect the pregnant woman. An arrow from the “pregnant woman” box points right, toward a box labeled “short- and long-term outcomes,” illustrating that all these factors come together to influence outcomes. The analytic framework was developed during AHRQ’s systematic evidence review on Outcomes of Maternal Weight Gain released in 2008. Research gaps were identified during the 2008 review and during a review, by the authors of the current report, of literature published since 2008. To the left of the “pregnant woman” box, on the center line, is a box labeled “anthropometric tools to measure adiposity during pregnancy.” Above the “pregnant woman” box, a series of arrows and boxes depicts societal factors. They are divided into four categories at the top of the figure: societal/institutional, environmental, neighborhood/community, and interpersonal/family. Each category contains two to four examples, such as media, environmental toxicants, access to healthy foods, and partner and family support. A pathway of boxes and arrows illustrates the influence of these factors on diet composition, energy intake, energy expenditure, and energy balance, which in turn affect the pregnant woman. Below the “pregnant woman” box, a box lists 14 maternal factors influencing the pregnant woman, such as demographic and health factors. An arrow from the “pregnant woman” box points right, to a box labeled “short- and long-term outcomes” and listing five outcomes: maternal antenatal and intrapartum outcomes, birth outcomes, infant health outcomes, child health outcomes, and maternal postpartum outcomes.

Methodological concerns related to measurement included the source of information on weight gain and the timing of measurement of weight gain. Studies that rely solely on self-reported pregravid and final pregnancy weights suffer from well-documented issues of recall bias. In addition, individuals tend to misreport their weight and at times height, and this bias varies by weight status92 and ethnicity.93 The timing of weight measurement (for pregravid weight and final weight) vary depending on the design of the study; when unreported, the total weight gain during pregnancy cannot be assumed to be collected at similar time points for all women within the study, resulting in further bias. Additional concerns include need for use of tools that are de rigeur in non-pregnancy weight and body habitus studies such as: standardization of weight measures including calibration of scales and stadiometers and introduction of use of anthropomorphic and other measures to assess body weight composition, distribution of body fat and patterns of weight gain.

## Consideration of Feasible Study Types for Addressing Gaps

Authors reflecting on research gaps in this area, as well as the experts who provided input for this report, note that the gold standard for establishing causation is to conduct randomized controlled trials at varied “exposures” to the causal agent under study. In this case to directly assess links between maternal weight gain and outcomes would require women be randomized to a particular weight gain target (and achieve the target). This has not been considered a feasible means to determine the influence of different levels of weight gain by women of varying pregravid weights on outcomes. If that is so, well-conducted observational studies continue to be necessary as one path to understanding associations and refining weight gain goals.

Observational studies bring with them a high bar for quality of measurement and rigor in statistical analysis in order correctly identify association with outcomes while accounting for confounding and modifying factors. Well-documented associations then have potential to serve as guides for the anticipated benefits and safety of trials that attempt behavioral, nutritional, or educational interventions to achieve desired target. Although the 2008 review included several studies that took advantage of large databases and longitudinal data that allowed investigation of the influence of weight gain on short- and long-term outcomes, it yielded little in the way of consistent findings because the body of research was assessed to lack methodological rigor, precision, concordance in findings and analytic sophistication.

## Summary

In summary the desire for evidence-based guidance about optimal maternal weight gain is important to women, their care providers, researchers, policy makers, and those who fund research and healthcare. It has special urgency given cultural trends in rising prevalence of overweight and obesity and given the public health repercussions of a population at increasing risk of chronic disease, earlier onset of those conditions, and resulting decreases in quality of life. There is a lack of definitive evidence about what factors in pregnancy exert most influence on outcomes, for example baseline weight or BMI, weight gain or patterns of weight gain, caloric or nutrient intake. This lack of evidence hinders ability to appropriately design and test interventions designed to modify the most critical components in order to improve fetal, neonatal, maternal, and childhood outcomes.

The future research needs project described in this report was undertaken to provide an overview of any fundamental changes in the state of the evidence since completion of the 2008 evidence review and to expand on identification of future research needs by engaging a group of experts from the range of disciplines that contribute to understand outcomes of maternal weight gain. These include nutritionists, reproductive epidemiologists, registered dietitians, multiple disciplines of prenatal care providers, researchers focused specifically on causal associations with maternal weight and weight gain, and others who study interventions to modify weight or nutritional intake. In the coming sections we describe our approach (1) to assessing whether there had been fundamental advances in the literature; (2) to compiling previously identified research gaps and soliciting identification of additional gaps; (3) to prioritizing among the many research needs identified; and (4) to discussing future research agendas and study designs that could be brought to bear on filling the gaps.