# Appendixes

Appendix A Search Strategy for Ongoing Studies

Appendix B List of Ongoing Studies

Appendix C Prioritization Tools and Results

Appendix D Excluded Studies