# Excluded Studies

1 Abstracts. Obstetrics & Gynecology. 2007;109(1):197-200. X-2.
2 Gestational weight gain and child adiposity. ACOG Clinical Review. 2007;12(5):13-13. X-2.
3 Gestational weight gain and neonatal outcome. ACOG Clinical Review. 2007;12(3):5-5. X-2.
4 Hot papers in the literature. Journal of Women’s Health (15409996). 2007;16(7):1076-1084. X-1.
5 Interpregnancy weight gain and adverse outcome. ACOG Clinical Review. 2007;12(4):4-5. X-2.
6 Literature review. Women’s Health Nurse Practitioner. 2007;32(6):19-19. X-2.
7 New in review. Periodicals Journal of the American Dietetic Association. 2007;107(3):512-517. X-2.
8 Obese mums given healthy lifestyle advice. Practising Midwife. 2007;10(9):13-13. X-2.
9 Research round-up. RCM Midwives. 2007;10(6):265-265. X-2.
10 2008 SNRS abstracts—A. Southern Online Journal of Nursing Research. 2008;8(4):1-1. X-2.
11 2008 SNRS abstracts—F–G. Southern Online Journal of Nursing Research. 2008;8(4):5-5. X-2.
12 2008 SNRS abstracts—H. Southern Online Journal of Nursing Research. 2008;8(4):6-6. X-2.
13 2008 SNRS abstracts—I–K. Southern Online Journal of Nursing Research. 2008;8(4):7-7. X-2.
14 2008 SNRS abstracts—T–V. Southern Online Journal of Nursing Research. 2008;8(4):13-13. X-2.
15 Abstracts. American Journal of Health Promotion. 2008;23(2):152-153. X-2.
16 Abstracts. Obstetrics & Gynecology. 2008;112(4):939-942. X-1.
17 Abstracts. Annals of Epidemiology. 2008;18(9):708-741. X-2.
18 Antepartum pulmonary embolism. ACOG Clinical Review. 2008;13(4):3-4. X-9.
19 Canadian Diabetes Association. Clinical Practice Guidelines for the Prevention and Management of Diabetes in Canada [corrected] [published erratum appears in Can J Diabetes 2009 Mar;33(1):46]. Canadian Journal of Diabetes. 2008. 2008;32:iv. X-2.
20 Gestational weight gain and normal body mass index. ACOG Clinical Review. 2008;13(3):3-3. X-2.
21 Gestational weight gain and obese women. ACOG Clinical Review. 2008;13(3):3-4. X-2.
22 Hot papers in the literature. Journal of Women’s Health (15409996). 2008;17(8):1409-1414. X-9.
23 New in review. Periodicals. Journal of the American Dietetic Association. 2008;108(4):728. X-1.
24 Obesity and spontaneous labor at term. ACOG Clinical Review. 2008;13(6):2-3. X-2.
25 Obesity linked to maternal deaths. Practising Midwife. 2008;11(1):7-7. X-2. [pmid: 18372811].
26 Obesity, multiple gestations may be factors in stillbirths. Contemporary OB/GYN. 2008;53(1):20-20. X-2. X-9.
27 Online. The latest web-only papers. Midwives. 2008;11(6):26-26. X-2.
28 Weight gain during pregnancy and obesity. ACOG Clinical Review. 2008;13(4):2-3. X-2.
29 Apparent disappearance of the black-white infant mortality gap - Dane County, Wisconsin, 1990–2007. MMWR Morb Mortal Wkly Rep. May. 29. 2009;58(20):561-5. X-1. [pmid: 19478725].
30 Bulletin board. Journal of Women’s Health (15409996). 2009;18(7):919-922. X-2.
31 Do fast food restaurants contribute to obesity. Natl Bur Econ Res Bull Aging Health. 2009:2-3. X-2. X-3. X-7. X-8. X-9.
32 Excessive weight gain and fetal macrosomia. ACOG Clinical Review. 2009;14(3):4-4. X-2.
33 High BMI. Midwifery Matters. 2009:25-27. X-2.
34 International news. Midwifery. 2009;25(5):469-472. X-2.
35 News breaks. Nutrition Today. Jan–Feb. 2009;44(1):4-5. X-2.
36 Obesity is a growing contributor to maternal morbidity in the industrialised world and beyond. International Midwifery. 2009;22(1):10-10. X-2.
37 Share with women. Women of size and pregnancy. Journal of Midwifery & Women’s Health. 2009;54(2):153-154. X-2.
38 Studies underline pregnancy risks for obese women. Practising Midwife. 2009;12(3):8-8. X-2.
39 Abeysena C, Jayawardana PRDAS. Maternal sleep deprivation is a risk factor for small for gestational age: a cohort study. Aust N Z J Obstet Gynaecol. Aug. 2009;49(4):382-387. X-6. [pmid: 19694692].
40 Abu Hamad K, Abed Y, Abu Hamad B. Risk factors associated with preterm birth in the Gaza Strip: hospital-based case-control study. East Mediterr Health J. Sep–Oct. 2007;13(5):1132-1141. X-6. [pmid: 18290407].
41 Adair LS, Martorell R, Stein AD, et al. Size at birth, weight gain in infancy and childhood, and adult blood pressure in 5 low- and middle-income-country cohorts: when does weight gain matter. Am J Clin Nutr. May. 2009;89(5):1383-1392. X-1. X-6. X-7. X-8. X-9. [pmid: 19297457].
42 Ainsworth S. Say goodbye to big babies: thanks to modern medical procedures. British Journal of Midwifery. 2007;15(6):384-384. X-1.
43 Akaboshi I, Haraguchi Y, Mizumoto Y, et al. Taller stature after postnatal rapid weight gain in early infancy predicts overweight status at age 3. Acta Paediatr. Oct. 2008;97(10):1460-1464. X-1. [pmid: 18624989].
44 Allen LH, Peerson JM, Olney DK. Provision of multiple rather than two or fewer micronutrients more effectively improves growth and other outcomes in micronutrient-deficient children and adults. J Nutr. May. 2009;139(5):1022-1030. X-7. [pmid: 19321586].
45 Alwan N, Tuffnell DJ, West J. Treatments for gestational diabetes [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4(4):X-2. X-9.
46 Amador N, Juarez JM, Guizar JM, et al. Quality of life in obese pregnant women: a longitudinal study. Am J Obstet Gynecol. Feb. 2008;198(2):203:e1-e5. X-6. [pmid: 17981249].
47 Amador-Licona N, Guizar-Mendoza JM, Juarez M, et al. Heart sympathetic activity and pulmonary function in obese pregnant women. Acta Obstetricia et Gynecologica Scandinavica. 2009;88(3):314-319. X-6. [pmid: 19241226].
48 Amorim Adegboye AR, Linne YM, Lourenco PMC. Diet or exercise, or both, for weight reduction in women after childbirth [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-1.
49 Amorim AR, Linne Y, Kac G, et al. Assessment of weight changes during and after pregnancy: practical approaches. Matern Child Nutr. Jan. 2008;4(1):1-13. X-2. [pmid: 18171403].
50 Andriessen P, Struis NC, Niemarkt H, et al. Furosemide in preterm infants treated with indomethacin for patent ductus arteriosus. Acta Paediatr. May. 2009;98(5):797-803. X-1. [pmid: 19187396].
51 Arendas K, Qiu Q, Gruslin A. Obesity in pregnancy: pre-conceptional to postpartum consequences. J Obstet Gynaecol Can. Jun. 2008;30(6):477-488. X-2. [pmid: 18611299].
52 Artal R, Lockwood CJ, Brown HL. Weight gain recommendations in pregnancy and the obesity epidemic. Obstet Gynecol. Jan. 2010;115(1):152-155. X-2. [pmid: 20027048].
53 Aschwald CL, Catanzaro RB, Weiss EP, et al. Large-for-gestational-age infants of type 1 diabetic mothers: an effect of preprandial hyperglycemia. Gynecol Endocrinol. Oct. 2009;25(10):653-660. X-5. X-6. [pmid: 19544119].
54 Ayers K. News for healthy living. Stay trim for the baby. Alternative Medicine Magazine. 2007(94):16-16. X-2.
55 Baker JL, Gamborg M, Heitmann BL, et al. Breastfeeding reduces postpartum weight retention. Am J Clin Nutr. Dec. 2008;88(6):1543-1551. X-9. [pmid: 19064514].
56 Barnett GC, Pharoah PDP. Influence of host-related factors on survival from breast cancer. American Journal of Hematology/Oncology. 2008;7(10):436-439. X-1.
57 Beard JH, Bell RL. Reproductive considerations and pregnancy after bariatric surgery: Current evidence and recommendations. Obesity Surgery. 2008;18(8):1023-1027. X-2. X-3. [pmid: 18392904].
58 Beardsall K, Ong KK, Murphy N, et al. Heritability of childhood weight gain from birth and risk markers for adult metabolic disease in prepubertal twins. J Clin Endocrinol Metab. Oct. 2009;94(10):3708-3713. X-1. [pmid: 19723754].
59 Belfort MB, Rifas-Shiman SL, Rich-Edwards JW, et al. Infant growth and child cognition at 3 years of age. Pediatrics. Sep. 2008;122(3):e689-e695. X-1. [pmid: 18762504].
60 Bell K, McNaughton D, Salmon A. Medicine, morality and mothering: public health discourses on foetal alcohol exposure, smoking around children and childhood overnutrition. Critical Public Health. 2009;19(2):155-170. X-2.
61 Benjamin SE, Rifas-Shiman SL, Taveras EM, et al. Early child care and adiposity at ages 1 and 3 years. Pediatrics. Aug. 2009;124(2):555-562. X-1. [pmid: 19651579].
62 Benko A. Waterbirth: is it a real choice. Midwifery Matters. 2009(122):9-12. X-1.
63 Bentley-Lewis R, Koruda K, Seely EW. The metabolic syndrome in women. Nature Clinical Practice Endocrinology and Metabolism. 2007;3(10):696-704. X-2.
64 Bertalan R, Patocs A, Boyle B, et al. The protective effect of the ER22/23EK polymorphism against an excessive weight gain during pregnancy. Gynecol Endocrinol. Jun. 2009;25(6):379-382. X-9. [pmid: 19241242].
65 Beyerlein A, Fahrmeir L, Mansmann U, et al. Alternative regression models to assess increase in childhood BMI. BMC Med Res Methodol. 2008;8:59. X-1. [pmid: 18778466].
66 Beyerlein A, Schiessl B, Lack N, et al. Optimal gestational weight gain ranges for the avoidance of adverse birth weight outcomes: a novel approach. Am J Clin Nutr. Dec. 2009;90(6):1552-1558. X-10. [pmid: 19812177].
67 Bhattacharya S, Campbell DM, Liston WA, et al. Effect of Body Mass Index on pregnancy outcomes in nulliparous women delivering singleton babies. BMC Public Health. 2007;7(168):X-11.
68 Bhogal K, Jayawardane IA. Obesity on obstetrics: new challenges and solutions using abdominal fetal ECG. Midwives. 2008;11(6):6p. X-2. [pmid: 24902148].
69 Black TL, Raine K, Willows ND. Understanding prenatal weight gain in First Nations women. Canadian Journal of Diabetes. 2008;32(3):198-205. X-5.
70 Borodulin K, Evenson KR, Herring AH. Physical activity patterns during pregnancy through postpartum. BMC Womens Health. 2009;9:32. X-1. X-9. [pmid: 19925650].
71 Bouhours-Nouet N, Dufresne S, de Casson FB, et al. High birth weight and early postnatal weight gain protect obese children and adolescents from truncal adiposity and insulin resistance: metabolically healthy but obese subjects. Diabetes Care. May. 2008;31(5):1031-1036. X-1. [pmid: 18223033].
72 Boutonnet M, Faitot V, Katz A, et al. Mallampati class changes during pregnancy, labour, and after delivery: can these be predicted. Br J Anaesth. Jan. 2010;104(1):67-70. X-1. X-3. X-9. [pmid: 20007793].
73 Brandon GD, Adeniyi-Jones S, Kirkby S, et al. Are outcomes and care processes for preterm neonates influenced by health insurance status. Pediatrics. Jul. 2009;124(1):122-127. X-1. [pmid: 19564291].
74 Buppasiri P, Lumbiganon P, Thinkhamrop J, et al. Calcium supplementation (other than for preventing or treating hypertension) for improving pregnancy and infant outcomes [Protocol]. Cochrane Database of Systematic Reviews. 2009;4:4. X-2.
75 Buttriss J. From feeding babies … to securing a sustainable global food supply. Nutrition Bulletin. 2009;34(4):337-339. X-1.
76 Calvo EB, Lopez LB, del Balmaceda YV, et al. Reference charts for weight gain and body mass index during pregnancy obtained from a healthy cohort. J Matern Fetal Neonatal Med. Jan. 2009;22(1):36-42. X-7. [pmid: 19089772].
77 Campos M, Reyes G, Garcia L. Comparison of postdischarge growth in adequate for gestational age and small for gestational age very low birthweight infants. Ethn Dis. Spring. 2008;18(2 Suppl 2):S2-118-S2-122. X-1. [pmid: 18646332].
78 Cantrell C, Kelley T, McDermott T. Midwifery management of the woman with an eating disorder in the antepartum period. J Midwifery Womens Health. Nov–Dec. 2009;54(6):503-508. X-6. [pmid: 19879524].
79 Carrascosa A, Audi L, Fernandez-Cancio M, et al. The exon 3-deleted/full-length growth hormone receptor polymorphism did not influence growth response to growth hormone therapy over two years in prepubertal short children born at term with adequate weight and length for gestational age. J Clin Endocrinol Metab. Mar. 2008;93(3):764-770. X-1. [pmid: 18160465].
80 Carvalho Padilha PD, Accioly E, Chagas C, et al. Birth weight variation according to maternal characteristics and gestational weight gain in Brazilian women. Nutr Hosp. Mar–Apr. 2009;24(2):207-212. X-7. [pmid: 19593493].
81 Casablanca Y. Management of Dysfunctional Uterine Bleeding Obstetrics and Gynecology Clinics of North America. 2008;35(2):219-234. X-1. [pmid: 18486838].
82 Casanueva E, Flores-Quijano ME, Rosello-Soberon ME, et al. Gestational weight gain as predicted by pregestational body mass index and gestational age in Mexican women. Food Nutr Bull. Dec. 2008;29(4):334-339. X-7. [pmid: 19227058].
83 Catalano PM. Management of obesity in pregnancy. Obstetrics and Gynecology. 2007;109:419-433. X-2. [pmid: 17267845].
84 Cena H, Toselli A, Bagnara A, et al. Assessment of weight gain during pregnancy: an Italian practical approach. Minerva Ginecol. Apr. 2009;61(2):97-107. X-2. X-3. X-7. X-8. X-9. [pmid: 19255557].
85 Christiansen JS. Insulin aspart: Rapid control for postmeal glucose excursions. Expert Review of Endocrinology and Metabolism. 2007;2(5):587-597. X-1.
86 Chu SY, Bachman DJ, Callaghan WM, et al. Obesity and cost of prenatal care. ACOG Clinical Review. 2008;13(5):2-3. X-2.
87 Chu SY, Callaghan WM, Bish CL, et al. Gestational weight gain by body mass index among US women delivering live births, 2004–2005 fueling future obesity. Am J Obstet Gynecol. Mar. 2009;200(3):271 e1-e7. X-9. [pmid: 19136091].
88 Cillié E, Jeanes YM, Meek J. Protein intake, growth and lung function of infants with chronic lung disease. Journal of Human Nutrition & Dietetics. 2009;22(3):264-265. X-1.
89 Claesson IM, Brynhildsen J, Cedergren M, et al. Weight gain restriction during pregnancy is safe for both the mother and neonate. Acta Obstet Gynecol Scand. 2009;88(10):1158-1162. X-10. [pmid: 19711205].
90 Claesson IM, Sydsjo G, Brynhildsen J, et al. Weight gain restriction for obese pregnant women: a case-control intervention study. BJOG. Jan. 2008;115(1):44-50. X-10. [pmid: 17970795].
91 Clark M, de Vries L, Lording R, et al. Research summaries. Breastfeeding Review. 2009;17(2):32-37. X-1. X-2. X-3. X-7. X-8. X-9.
92 Clift-Mathews V. Bump or bulge? Battling obesity in pregnancy. British Journal of Midwifery. 2009;17(3):140. X-2.
93 Clift-Matthews V. Fat is a family issue. British Journal of Midwifery. 2009;17(6):344. X-2.
94 Cohain JS. Can a low glycaemic diet in pregnancy increase VBAC success. MIDIRS Midwifery Digest. 2009;19(1):71-74. X-2.
95 Collado MC, Isolauri E, Laitinen K, et al. Distinct composition of gut microbiota during pregnancy in overweight and normal-weight women. Am J Clin Nutr. Oct. 2008;88(4):894-899. X-9. [pmid: 18842773].
96 Collins CT, Gibson RA, Miller J, et al. Carbohydrate intake is the main determinant of growth in infants born <33 weeks’ gestation when protein intake is adequate. Nutrition. May. 2008;24(5):451-457. X-1. [pmid: 18329853].
97 Cox JT, Phelan ST. Nutrition during pregnancy. Obstet Gynecol Clin North Am. Sep. 2008;35(3):369-383. viii. X-2. [pmid: 18760225].
98 Cramer JA, Gordon J, Schachter S, et al. Women with epilepsy: Hormonal issues from menarche through menopause. Epilepsy and Behavior. 2007;11(2):160-178. X-1. X-2. [pmid: 17662661].
99 Crncevic-Orlic Z, Ruzic A, Miletic B, et al. Predictive parameters of gestational diabetes mellitus. Coll Antropol. Sep. 2007;31(3):771-774. X-7. [pmid: 18041387].
100 Crossland DS, Richmond S, Hudson M, et al. Weight change in the term baby in the first 2 weeks of life. Acta Paediatr. Apr. 2008;97(4):425-429. X-1. [pmid: 18363951].
101 Crouch P, O’Dea JA, Battisti R. Child feeding practices and perceptions of childhood overweight and childhood obesity risk among mothers of preschool children. Nutrition & Dietetics. 2007;64(3):151-158. X-1.
102 Cullum A. Weight management during and after pregnancy. British Journal of Midwifery. 2009;17(6):367-368. X-2.
103 Davis E, Olson C. Obesity in pregnancy. Prim Care. Jun. 2009;36(2):341-356. X-2. X-3. X-7. X-8. X-9. [pmid: 19501247].
104 de Beer M, van Eijsden M, Vrijkotte TG, et al. Early growth patterns and cardiometabolic function at the age of 5 in a multiethnic birth cohort: the ABCD study. BMC Pediatr. 2009;9:23. X-1. [pmid: 19317894].
105 de Kort SW, Hokken-Koelega AC. The PPAR-gamma Pro12Ala polymorphism associates with weight gain during GH-treatment in short children born small for gestational age. Eur J Endocrinol. Jan. 2010;162(1):49-52. X-1. [pmid: 19808901].
106 De Schepper J, Thomas M, Beckers D, et al. Growth hormone treatment and fat redistribution in children born small for gestational age. J Pediatr. Mar. 2008;152(3):327-330. X-1. [pmid: 18280835].
107 Deaver JE, Cohen WR. An approach to the prediction of neonatal Erb palsy. J Perinat Med. 2009;37(2):150-155. X-10. [pmid: 18976046].
108 Deierlein AL, Siega-Riz AM, Herring A. Dietary energy density but not glycemic load is associated with gestational weight gain. Am J Clin Nutr. Sep. 2008;88(3):693-699. X-9. [pmid: 18779285].
109 Demerath EW, Jones LL, Hawley NL, et al. Rapid infant weight gain and advanced skeletal maturation in childhood. J Pediatr. Sep. 2009;155(3):355-361. X-1. [pmid: 19446851].
110 Derbyshire E. Low maternal weight: effects on maternal and infant health during pregnancy. Nurs Stand. Sep 26–Oct 2. 2007;22(3):43-46. X-2. X-3. X-7. X-8. [pmid: 17966921].
111 Derbyshire E, Davies GJ, Costarelli V, et al. Habitual micronutrient intake during and after pregnancy in Caucasian Londoners. Matern Child Nutr. Jan. 2009;5(1):1-9. X-1. X-9. [pmid: 19161540].
112 DeVader SR, Neeley HL, Myles TD, et al. Evaluation of gestational weight gain guidelines for women with normal prepregnancy body mass index. Obstet Gynecol. Oct. 2007;110(4):745-751. X-5. [pmid: 17906004].
113 Di Lillo M, Hendrix N, O’Neill M, et al. Pregnancy in obese women: what you need to know. Contemporary OB/GYN. 2008;53(11):48-53. X-2.
114 Dias MC, de Fazio ES, de Oliveira FC, et al. Body weight changes and outcome of pregnancy after gastroplasty for morbid obesity. Clin Nutr. Apr. 2009;28(2):169-172. X-5. [pmid: 19233524].
115 Dikensoy E, Balat O, Cebesoy B, et al. The effect of Ramadan fasting on maternal serum lipids, cortisol levels and fetal development. Arch Gynecol Obstet. Feb. 2009;279(2):119-123. X-7. [pmid: 18488237].
116 Doshani A, Konje JC. Diabetes in pregnancy: insulin resistance, obesity and placental dysfunction. British Journal of Diabetes & Vascular Disease. 2009;9(5):208-212. X-2.
117 Doumouchtsis SK, Arulkumaran S. Are all brachial plexus injuries caused by shoulder dystocia, Obstet Gynecol Surv. Sep. 2009;64(9):615-623. X-2.
118 Duff E. A worldwide look at what is happening in midwifery. All unequal but some more unequal than others: maternal health risks in life style and culture. MIDIRS Midwifery Digest. 2009;19(1):43-44. X-1.
119 Dunaif A. Drug Insight: Insulin-sensitizing drugs in the treatment of polycystic ovary syndrome—A reappraisal. Nature Clinical Practice Endocrinology and Metabolism. 2008;4(5):272-283. X-2.
120 Dwarkanath P, Kurpad AV, Muthayya S, et al. Glucose kinetics and pregnancy outcome in Indian women with low and normal body mass indices. Eur J Clin Nutr. Nov. 2009;63(11):1327-1334. X-3. X-6. [pmid: 19471289].
121 Dwarkanath P, Muthayya S, Vaz M, et al. The relationship between maternal physical activity during pregnancy and birth weight. Asia Pac J Clin Nutr. 2007;16(4):704-710. X-7. [pmid: 18042532].
122 Egerman RS, Ramsey RD, Kao LW, et al. Perinatal outcomes in pregnancies managed with antenatal insulin glargine. American Journal of Perinatology. 2009;26(8):591-595. X-6. [pmid: 19370512].
123 Einarson A, Boskovic R. Use and safety of antipsychotic drugs during pregnancy. Journal of Psychiatric Practice. 2009;15(3):183-192. X-1. X-2. [pmid: 19461391].
124 Farrar D, Duley L, Lawlor DA. Alternative strategies for diagnosing gestational diabetes mellitus to improve maternal and infant health [Protocol]. Cochrane Database of Systematic Reviews. 2009;4:4. X-2.
125 Feldt K, Raikkonen K, Eriksson JG, et al. Childhood growth and cardiovascular reactivity to psychological stressors in late adulthood. J Intern Med. Jul. 2008;264(1):72-82. X-1. [pmid: 18298488].
126 Fernandez ID, Olson CM, De Ver Dye T. Discordance in the assessment of prepregnancy weight status of adolescents: a comparison between the Centers for Disease Control and Prevention sex- and age-specific body mass index classification and the Institute of Medicine-based classification used for maternal weight gain guidelines J Am Diet Assoc. Jun. 2008;108(6):998-1002. X-9.
127 Fine JB. The influence of periodontal inflammation on systemic diseases and medical conditions. Access. 2007;21(5):14-19. X-1. X-2.
128 Fischer MA. Implanon: a new contraceptive implant. J Obstet Gynecol Neonatal Nurs. May–Jun. 2008;37(3):361-368. X-1.
129 Fontein Y. A clinical decision: making sense of decisions made through reflective practice. MIDIRS Midwifery Digest. 2008;18(1):35-38. X-2. X-3. X-7. X-8. X-9.
130 Ford S. Gestational diabetes linked to child obesity. Nursing Times. 2007;103(36):7-7. X-2. [pmid: 17993110].
131 Fortes Filho JB, Bonomo PP, Maia M, et al. Weight gain measured at 6 weeks after birth as a predictor for severe retinopathy of prematurity: study with 317 very low birth weight preterm babies. Graefes Arch Clin Exp Ophthalmol. Jun. 2009;247(6):831-836. X-1. [pmid: 19052770].
132 Frischknecht F, Bruhwiler H, Raio L, et al. Changes in pre-pregnancy weight and weight gain during pregnancy: retrospective comparison between 1986 and 2004. Swiss Med Wkly. Jan. 24. 3. 2009:139-4. 52. 55. X-10.
133 Fuiano N, Rapa A, Monzani A, et al. Prevalence and risk factors for overweight and obesity in a population of Italian schoolchildren: a longitudinal study. J Endocrinol Invest. Nov. 2008;31(11):979-984. X-10. [pmid: 19169053].
134 Gagnon AJ, Sandall J. Individual or group antenatal education for childbirth or parenthood, or both [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-1.
135 Galtier F, Raingeard I, Renard E, et al. Optimizing the outcome of pregnancy in obese women: from pregestational to long-term management. Diabetes Metab. Feb. 2008;34(1):19-25. X-2. [pmid: 18242113].
136 Gavard JA, Artal R. Effect of exercise on pregnancy outcome. Clin Obstet Gynecol. Jun. 2008;51(2):467-480. X-2. X-3. X-7. X-8. X-9. [pmid: 18463475].
137 Getahun D, Ananth CV, Oyelese Y, et al. Primary preeclampsia in the second pregnancy: effects of changes in prepregnancy body mass index between pregnancies. Obstet Gynecol. Dec. 2007;110(6):1319-1325. X-9. [pmid: 18055727].
138 Gillman MW, Rifas-Shiman SL, Kleinman K, et al. Developmental origins of childhood overweight: potential public health impact. Obesity (Silver Spring). Jul. 2008;16(7):1651-1656. X-10. [pmid: 18451768].
139 Giroux I, Lander S, Charlesworth S, et al. Weight history of overweight pregnant women. Can J Diet Pract Res. Autumn. 2009;70(3):127-134. X-9. [pmid: 19709468].
140 Goldenberg N, Glueck C. Medical therapy in women with polycystic ovarian syndrome before and during pregnancy and lactation. Minerva Ginecologica. 2008;60(1):63-75. X-2. [pmid: 18277353].
141 Gollenberg A, Pekow P, Markenson G, et al. Dietary behaviors, physical activity, and cigarette smoking among pregnant Puerto Rican women. Am J Clin Nutr. Jun. 2008;87(6):1844-1851. X-9. [pmid: 18541576].
142 Gonzalez AP, Vasquez-Mendoza G, Garcia-Vela A, et al. Weight gain in preterm infants following parent-administered Vimala massage: a randomized controlled trial. Am J Perinatol. Apr. 2009;26(4):247-252. X-1. [pmid: 19023851].
143 Greer FR. Long-term adverse outcomes of low birth weight, increased somatic growth rates, and alterations of body composition in the premature infant: review of the evidence. J Pediatr Gastroenterol Nutr. Dec. 2007;45(Suppl 3):S147-151. X-1. [pmid: 18185081].
144 Guelinckx I, Devlieger R, Vansant G. Reproductive outcome after bariatric surgery: a critical review. Hum Reprod Update. Mar–Apr. 2009;15(2):189-201. X-2. X-3. X-7. X-8. X-9. [pmid: 19136457].
145 Guilfoy VM, Wright-Coltart S, Leitch CA, et al. Energy expenditure in extremely low birth weight infants near time of hospital discharge. J Pediatr. Nov. 2008;153(5):612-615. X-1. X-5. [pmid: 18657827].
146 Gumus II, Turhan NO. Are patients with positive screening but negative diagnostic test for gestational diabetes under risk for adverse pregnancy outcome. J Obstet Gynaecol Res. Jun. 2008;34(3):359-363. X-6. [pmid: 18588612].
147 Gunderson EP, Jacobs DR Jr, Chiang V, et al. Childbearing is associated with higher incidence of the metabolic syndrome among women of reproductive age controlling for measurements before pregnancy: the CARDIA study. Am J Obstet Gynecol. Aug. 2009;201(2):177 e1-e9. X-9. [pmid: 19560114].
148 Gunderson EP, Rifas-Shiman SL, Oken E, et al. Association of fewer hours of sleep at 6 months postpartum with substantial weight retention at 1 year postpartum. Am J Epidemiol. Jan. 15. 2008;167(2):178-187. X-1. [pmid: 17971337].
149 Gungor ES, Danisman N, Mollamahmutoglu L. Maternal serum ferritin and hemoglobin values in patients with gestational diabetes mellitus. Saudi Medical Journal. 2007;28(3):478-480. X-1. X-6. X-9. [pmid: 17334491].
150 Haakstad LA, Voldner N, Henriksen T, et al. Why do pregnant women stop exercising in the third trimester. Acta Obstet Gynecol Scand. 2009;88(11):1267-1275. X-9. [pmid: 19824869].
151 Haedt A, Keel P. Maternal attachment, depression, and body dissatisfaction in pregnant women. Journal of Reproductive & Infant Psychology. 2007;25(4):285-295. X-2.
152 Haeri S, Guichard I, Baker AM, et al. The effect of teenage maternal obesity on perinatal outcomes. Obstet Gynecol. Feb. 2009;113(2 Pt 1):300-304. X-9. [pmid: 19155898].
153 Hahn HS, Yoon SG, Hong JS, et al. Conservative treatment with progestin and pregnancy outcomes in endometrial cancer. International Journal of Gynecological Cancer. 2009;19(6):1068-1073. X-1. X-5. [pmid: 19820370].
154 Hancox RJ, Poulton R, Greene JM, et al. Associations between birth weight, early childhood weight gain and adult lung function. Thorax. Mar. 2009;64(3):228-232. X-1. [pmid: 19052051].
155 Hanson L. Conference Proceedings: Abstracts from Research Forums Presented at the ACNM 52nd Annual Meeting 2007. Journal of Midwifery and Women’s Health. 2007;52(5):531-535. X-1.
156 Haslam D. Obesity, diabetes and maternal deaths. Practical Diabetes International. 2008;25(3):87-89. X-2.
157 Haworth CM, Plomin R, Carnell S, et al. Childhood obesity: genetic and environmental overlap with normal-range BMI. Obesity (Silver Spring). Jul. 2008;16(7):1585-1590. X-1. [pmid: 18421262].
158 Hawthorne G. Preconception care in diabetes. Practice Nursing. 2009;20(8):402-405. X-1.
159 Hay-Smith J, Morkved S, Fairbrother KA, et al. Pelvic floor muscle training for prevention and treatment of urinary and faecal incontinence in antenatal and postnatal women [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-1.
160 Heaman M. The effect of gestational weight gain by body mass index on maternal and neonatal outcomes. MCN: The American Journal of Maternal Child Nursing. 2009;34(5):329-329. X-2.
161 Hedderson MM, Williams MA, Holt VL, et al. Body mass index and weight gain prior to pregnancy and risk of gestational diabetes mellitus. Am J Obstet Gynecol. Apr. 2008;198(4):409 e1-e7. X-1. [pmid: 18068138].
162 Heimonen A, Rintamaki H, Furuholm J, et al. Postpartum oral health parameters in women with preterm birth. Acta Odontol Scand. 2008;66(6):334-341. X-1. [pmid: 18720047].
163 Helder OK, Mulder PG, van Goudoever JB. Computer-generated versus nurse-determined strategy for incubator humidity and time to regain birthweight. J Obstet Gynecol Neonatal Nurs. May–Jun. 2008;37(3):255-261. X-1.
164 Hellwig JP. On the edge. Gestational diabetes and childhood obesity. Nursing for Women’s Health. 2007;11(6):540-540. X-2. X-3.
165 Helmreich RJ. Obesity on vagal tone and Hb A1c during pregnancy. Southern Online Journal of Nursing Research. 2008;8(2):2. X-2. X-9.
166 Henriksen T. The macrosomic fetus: a challenge in current obstetrics. Acta Obstet Gynecol Scand. 2008;87(2):134-145. X-2. X-3. X-7. X-8. X-9. [pmid: 18231880].
167 Herring SJ, Rich-Edwards JW, Oken E, et al. Association of postpartum depression with weight retention 1 year after childbirth. Obesity (Silver Spring). Jun. 2008;16(6):1296-1301. X-1. [pmid: 18369338].
168 Hillier TA, Pedula KL, Vesco KK, et al. Excess gestational weight gain: Modifying fetal macrosomia risk associated with maternal glucose. Obstetrics and Gynecology. 2008;112(5):1007-1014. X-10. [pmid: 18978099].
169 Hirschberg AL. Polycystic ovary syndrome, obesity and reproductive implications. Women’s Health. 2009;5(5):529-542. X-1.
170 Horta BL, Gigante DP, Osmond C, et al. Intergenerational effect of weight gain in childhood on offspring birthweight. Int J Epidemiol. Jun. 2009;38(3):724-732. X-1. X-7. [pmid: 19376883].
171 Horta BL, Sibbritt DW, Lima RC, et al. Weight catch-up and achieved schooling at 18 years of age in Brazilian males. Eur J Clin Nutr. Mar. 2009;63(3):369-374. X-1. X-7. [pmid: 17957192].
172 Horta BL, Victora CG, Lima RC, et al. Weight gain in childhood and blood lipids in adolescence. Acta Paediatr. Jun. 2009;98(6):1024-1028. X-1. X-7. [pmid: 19484844].
173 Horvath EM, Magenheim R, Kugler E, et al. Nitrative stress and poly(ADP-ribose) polymerase activation in healthy and gestational diabetic pregnancies. Diabetologia. Sep. 2009;52(9):1935-1943. X-1. [pmid: 19597800].
174 Hyer SL, Balani J, Johnson A, et al. Metformin treatment for gestational diabetes. British Journal of Diabetes & Vascular Disease. 2009;9(5):220-225. X-2. X-9.
175 Irlam JJH, Visser MME, Rollins NN, et al. Micronutrient supplementation in children and adults with HIV infection [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-1. X-2.
176 Isaranurug S, Mo-suwan L, Choprapawon C. A population-based cohort study of effect of maternal risk factors on low birthweight in Thailand. J Med Assoc Thai. Dec. 2007;90(12):2559-2564. X-7. [pmid: 18386704].
177 James RJ, James A, Drewett RF, et al. Milk intake and feeding behavior in the first week of life and its relationship to cord blood ghrelin, leptin, and insulin concentrations. Pediatr Res. Dec. 2007;62(6):695-699. X-1. [pmid: 17957153].
178 Jaruratanasirikul S, Sangsupawanich P, Koranantakul O, et al. Influence of maternal nutrient intake and weight gain on neonatal birth weight: a prospective cohort study in southern Thailand. J Matern Fetal Neonatal Med. Nov. 2009;22(11):1045-1050. X-7. [pmid: 19900042].
179 Jevitt C. Pregnancy complicated by obesity: midwifery management. J Midwifery Womens Health. Nov–Dec. 2009;54(6):445-451. X-2. X-3. X-7. X-9. [pmid: 19879516].
180 Johnson N. Thoughts on the obesity epidemic. British Journal of Midwifery. 2009;17(6):370-371. X-1. X-2. X-3. X-7. X-8. X-9.
181 Joyce T, Racine A, Yunzal-Butler C. Reassessing the WIC effect: evidence from the Pregnancy Nutrition Surveillance System. J Policy Anal Manage. Spring. 2008;27(2):277-303. X-9. [pmid: 18401924].
182 Kac G, Nucci LB, Spyrides MH, et al. Evaluation of the ability of a Latin-American gestational weight curve to predict adverse pregnancy outcomes. Int J Gynaecol Obstet. Sep. 2009;106(3):223-226. X-7. [pmid: 19476947].
183 Kaiser L, Allen LH. Position of the American Dietetic Association: nutrition and lifestyle for a healthy pregnancy outcome. J Am Diet Assoc. Mar. 2008;108(3):553-561. X-2. [pmid: 18401922].
184 Kalliomaki M, Collado MC, Salminen S, et al. Early differences in fecal microbiota composition in children may predict overweight. Am J Clin Nutr. Mar. 2008;87(3):534-538. X-1. [pmid: 18326589].
185 Kamanu CI, Onwere S, Chigbu B, et al. Fetal macrosomia in African women: a study of 249 cases. Arch Gynecol Obstet. Jun. 2009;279(6):857-861. X-7. [pmid: 19018549].
186 Karaolis-Danckert N, Buyken AE, Kulig M, et al. How pre- and postnatal risk factors modify the effect of rapid weight gain in infancy and early childhood on subsequent fat mass development: results from the Multicenter Allergy Study 90. Am J Clin Nutr. May. 2008;87(5):1356-1364. X-1. [pmid: 18469259].
187 Karaolis-Danckert N, Gunther AL, Kroke A, et al. How early dietary factors modify the effect of rapid weight gain in infancy on subsequent body-composition development in term children whose birth weight was appropriate for gestational age. Am J Clin Nutr. Dec. 2007;86(6):1700-1708. X-1. [pmid: 18065589].
188 Kelly CY, Clancy CM. Importance of recommendations for gestational weight gain. J Nurs Care Qual. Apr–Jun. 2009;24(2):96-99. X-2. X-3. X-7. X-8. X-9. [pmid: 19287245].
189 Kelsey B. What are the most important issues in counseling women about oral contraception? Women’s Health Care:. A Practical Journal for Nurse Practitioners. 2007;6(12):8-23. X-2.
190 Kennedy D. Antipsychotic drugs in pregnancy and breastfeeding. Australian Prescriber. 2007;30(6):162-163. X-1. X-2.
191 Khodakarami N, Naji H, Dashti MG, et al. Woman abuse and pregnancy outcome among women in Khoram Abad, Islamic Republic of Iran. East Mediterr Health J. May–Jun. 2009;15(3):622-628. X-7. [pmid: 19731778].
192 Kiel DW, Dodson EA, Artal R, et al. Gestational weight gain and pregnancy outcomes in obese women: how much is enough. Obstet Gynecol. Oct. 2007;110(4):752-758. X-5. [pmid: 17906005].
193 Kim KH, Kim YJ, Lee S, et al. Evaluation of plasma leptin levels and BMI as predictor of postpartum weight retention. Indian Journal of Medical Research. 2008;128(5):595-600. X-7. [pmid: 19179678].
194 Kinnunen TI, Aittasalo M, Koponen P, et al. Feasibility of a controlled trial aiming to prevent excessive pregnancy-related weight gain in primary health care. BMC Pregnancy Childbirth. 2008;8:37. X-9. [pmid: 18694479].
195 Kipps S. Prescribing the contraceptive pill. Practice Nursing. 2008;19(7):346. X-1. X-5.
196 Kramer MS. Energy/protein restriction for high weight-for-height or weight gain during pregnancy [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-9.
197 Kramer MS. High protein supplementation in pregnancy [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-9.
198 Kramer MS. Isocaloric balanced protein supplementation in pregnancy [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-9.
199 Kramer MS. Nutritional advice in pregnancy [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-9.
200 Kramer MS, Kakuma R. Maternal dietary antigen avoidance during pregnancy or lactation, or both, for preventing or treating atopic disease in the child [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-1.
201 Kramer MS, McDonald SW. Aerobic exercise for women during pregnancy [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-9.
202 Kuehn BM. Guideline for pregnancy weight gain offers targets for obese women. JAMA. Jul. 15. 2009;302(3):241-242. X-2. X-3. [pmid: 19602677].
203 Kuhlmann AK, Dietz PM, Galavotti C, et al. Weight-management interventions for pregnant or postpartum women. Am J Prev Med. Jun. 2008;34(6):523-528. X-2. X-3. X-9. [pmid: 18471590].
204 Langer O. From educated guess to accepted practice: The use of oral antidiabetic agents in pregnancy. Clinical Obstetrics and Gynecology. 2007;50(4):959-971. X-1. X-2. [pmid: 17982339].
205 Langer O. Management of obesity in GDM: old habits die hard. J Matern Fetal Neonatal Med. Mar. 2008;21(3):165-171. X-2. [pmid: 18297571].
206 Langer O. Type 2 diabetes in pregnancy: Exposing deceptive appearances. Journal of Maternal Fetal and Neonatal Medicine. 2008;21(3):181-189. X-2. X-6. [pmid: 18297573].
207 Lansang CM, Kennedy L. Insulin glargine: A basal insulin for the management of diabetes. Expert Review of Endocrinology and Metabolism. 2007;2(5):573-585. X-1.
208 Le YC, Rahman M, Berenson AB. Early weight gain predicting later weight gain among depot medroxyprogesterone acetate users. Obstet Gynecol. Aug. 2009;114(2 Pt 1):279-284. X-1. [pmid: 19622988].
209 Legro RS. Metformin for infertility in PCOS: going, going, gone. Contemporary OB/GYN. 2007;52(12):54. X-1.
210 LeRoith D. Gender differences in metabolic disorders. Gender Medicine. 2009;6:1-3. X-1. X-2. X-3. X-7. X-8. X-9. [pmid: 19318215].
211 Leung G. National Obesity Forum 6th Annual Conference: obesity: the scourge of modern civilisation. Nutrition Bulletin. 2009;34(1):97-102. X-2. X-3. X-7. X-8. X-9.
212 Leunissen RW, Kerkhof GF, Stijnen T, et al. Timing and tempo of first-year rapid growth in relation to cardiovascular and metabolic risk profile in early adulthood. JAMA. Jun. 3. 2009;301(21):2234-2242. X-1. X-6. [pmid: 19491185].
213 Leunissen RW, Stijnen T, Boot AM, et al. Influence of birth size and body composition on bone mineral density in early adulthood: the PROGRAM study. Clin Endocrinol (Oxf). Sep. 2008;69(3):386-392. X-1. [pmid: 18284639].
214 Leunissen RW, Stijnen T, Hokken-Koelega AC. Influence of birth size on body composition in early adulthood: the programming factors for growth and metabolism (PROGRAM)-study. Clin Endocrinol (Oxf). Feb. 2009;70(2):245-251. X-1. [pmid: 18616715].
215 Lin CH, Wen SF, Wu YH, et al. Using the 100-g oral glucose tolerance test to predict fetal and maternal outcomes in women with gestational diabetes mellitus. Chang Gung Med J. May–Jun. 2009;32(3):283-289. X-6. [pmid: 19527607].
216 Lockwood CJ. Dealing with a weighty issue. Contemporary OB/GYN. 2009;54(8):10. X-2. X-3. X-7. X-8.
217 Lof M, Hilakivi-Clarke L, Sandin S, et al. Effects of pre-pregnancy physical activity and maternal BMI on gestational weight gain and birth weight. Acta Obstet Gynecol Scand. 2008;87(5):524-530. X-10. [pmid: 18446535].
218 Lomangino K. Obese women advised to limit weight gain during pregnancy. Clinical Nutrition Insight. 2009;35(9):5. X-2. X-3. X-7. X-8. X-9.
219 Lomas C. Obesity linked to antenatal PE. Nursing Times. 2008;104(8):6-6. X-2. X-3. X-7. X-8. X-9. [pmid: 18833720].
220 Loui A, Tsalikaki E, Maier K, et al. Growth in high risk infants <1500 g birthweight during the first 5 weeks. Early Hum Dev. Oct. 2008;84(10):645-650. X-1. [pmid: 18539413].
221 Lumley J, Chamberlain C, Dowswell T, et al. Interventions for promoting smoking cessation during pregnancy [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;4:4. X-1.
222 Lyu LC, Lo CC, Chen HF, et al. A prospective study of dietary intakes and influential factors from pregnancy to postpartum on maternal weight retention in Taipei, Taiwan. Br J Nutr. Dec. 2009;102(12):1828-1837. X-7. [pmid: 19678967].
223 Mahmood TA. Obesity and pregnancy: an obstetrician's view. British Journal of Diabetes & Vascular Disease 2009. Jan–Feb. 2009;9(1):19-20. X-2.
224 Malcolm WF, Smith PB, Mears S, et al. Transpyloric tube feeding in very low birthweight infants with suspected gastroesophageal reflux: impact on apnea and bradycardia. J Perinatol. May. 2009;29(5):372-375. X-1. [pmid: 19242488].
225 Malik S. Impact of obesity on female fertility and fertility treatment. British Journal of Midwifery. 2009;17(7):452-454. X-1. X-2.
226 Manios Y, Grammatikaki E, Kondaki K, et al. The effect of maternal obesity on initiation and duration of breast-feeding in Greece: the GENESIS study. Public Health Nutr. Apr. 2009;12(4):517-524. X-9. [pmid: 18547456].
227 Mantzoros CS, Rifas-Shiman SL, Williams CJ, et al. Cord blood leptin and adiponectin as predictors of adiposity in children at 3 years of age: a prospective cohort study. Pediatrics. Feb. 2009;123(2):682-689. X-1. [pmid: 19171638].
228 Marcus SM. Depression during pregnancy: rates, risks and consequences--Motherisk Update 2008. Can J Clin Pharmacol. Winter. 2009;16(1):e15-e22. X-2. X-6. [pmid: 19164843].
229 Massaro AN, Hammad TA, Jazzo B, et al. Massage with kinesthetic stimulation improves weight gain in preterm infants. J Perinatol. May. 2009;29(5):352-357. X-1. [pmid: 19148112].
230 Mastorakos G, Valsamakis G, Papatheodorou DC, et al. The role of adipocytokines in insulin resistance in normal pregnancy: Visfatin concentrations in early pregnancy predict insulin sensitivity. Clinical Chemistry. 2007;53(8):1477-1483. X-3. [pmid: 17586594].
231 Meas T, Deghmoun S, Armoogum P, et al. Consequences of being born small for gestational age on body composition: an 8-year follow-up study. J Clin Endocrinol Metab. Oct. 2008;93(10):3804-3809. X-1. [pmid: 18628518].
232 Megia A, Vendrell J, Gutierrez C, et al. Insulin sensitivity and resistin levels in gestational diabetes mellitus and after parturition. Eur J Endocrinol. Feb. 2008;158(2):173-178. X-1. [pmid: 18230823].
233 Mehta SH. Nutrition and pregnancy. Clin Obstet Gynecol. Jun. 2008;51(2):409-418. X-2. X-3. X-7. X-8. X-9. [pmid: 18463470].
234 Modi P. Future therapeutic directions: New medications and insulin delivery in a changing world for effective diabetes management. Current Drug Discovery Technologies. 2009;6(3):200-213. X-1. [pmid: 19496750].
235 Mok E, Multon C, Piguel L, et al. Decreased full breastfeeding, altered practices, perceptions, and infant weight change of prepregnant obese women: a need for extra support. Pediatrics. May. 2008;121(5):e1319-e1324. X-9. [pmid: 18450874].
236 Montouris G, Abou-Khalil B. The first line of therapy in a girl with juvenile myoclonic epilepsy: should it be valproate or a new agent. Epilepsia. Sep. 2009;50(Suppl 8):16-20. X-1. X-2. X-6. [pmid: 19702728].
237 Muktabhant B, Lumbiganon P, Ngamjarus C. Interventions for preventing excessive weight gain during pregnancy [Protocol]. Cochrane Database of Systematic Reviews. 2009;4:4. X-2.
238 Mumford SL, Siega-Riz AM, Herring A, et al. Dietary restraint and gestational weight gain. J Am Diet Assoc. Oct. 2008;108(10):1646-1653. X-9. [pmid: 18926129].
239 Muthayya S, Dwarkanath P, Thomas T, et al. The effect of fish and omega-3 LCPUFA intake on low birth weight in Indian pregnant women. Eur J Clin Nutr. Mar. 2009;63(3):340-346. X-7. [pmid: 17957193].
240 Nahar S, Mascie-Taylor CG, Begum HA. Impact of targeted food supplementation on pregnancy weight gain and birth weight in rural Bangladesh: an assessment of the Bangladesh Integrated Nutrition Program (BINP). Public Health Nutr. Aug. 2009;12(8):1205-1212. X-7. [pmid: 18838027].
241 Nawab US, Greenspan JS, Kirkby S, et al. Differences in short-term neonatal outcomes between discordant twins. Adv Neonatal Care. Dec. 2008;8(6):334-342. X-1. [pmid: 19060578].
242 New K, Flenady V, Davies MW. Transfer of preterm infants from incubator to open cot at lower versus higher body weight. Cochrane Database Syst Rev. 2008;(1):CD004214. X-1. [pmid: 18254041].
243 Nien JK, Mazaki-Tovi S, Romero R, et al. Plasma adiponectin concentrations in non-pregnant, normal and overweight pregnant women. J Perinat Med. 2007;35(6):522-531. X-1. X-9. [pmid: 17919116].
244 Oken E. Excess gestational weight gain amplifies risks among obese mothers. Epidemiology. Jan. 2009;20(1):82-83. X-2. [pmid: 18813018].
245 Oken E. Maternal and child obesity: the causal link. Obstet Gynecol Clin North Am. Jun. 2009;36(2):361-377. ix-x. X-3. X-7. X-8. [pmid: 19501319].
246 Olsen SF, Halldorsson TI, Willett WC, et al. Milk consumption during pregnancy is associated with increased infant size at birth: prospective cohort study. Am J Clin Nutr. Oct. 2007;86(4):1104-1110. X-9. [pmid: 17921389].
247 Olson CM. A call for intervention in pregnancy to prevent maternal and child obesity. Am J Prev Med. Nov. 2007;33(5):435-436. X-2. [pmid: 17950410].
248 Olson CM. Achieving a healthy weight gain during pregnancy. Annu Rev Nutr. 2008;28:411-423. X-2. X-3. X-7. X-8. X-9. [pmid: 18422452].
249 Olson CM, Strawderman MS, Dennison BA. Maternal weight gain during pregnancy and child weight at age 3 years. Matern Child Health J. Nov. 2009;13(6):839-846. X-10. [pmid: 18818995].
250 Ong GKB, Hamilton JK, Sermer M, et al. Maternal serum adiponectin and infant birthweight: The role of adiponectin isoform distribution. Clinical Endocrinology. 2007;67(1):108-114. X-3. [pmid: 17466005].
251 Oostdam N, van Poppel MNM, Eekhoff EMW, et al. Design of FitFor2 study: The effects of an exercise program on insulin sensitivity and plasma glucose levels in pregnant women at high risk for gestational diabetes. BMC Pregnancy and Childbirth. 2009;9(1):X-2. X-3. X-7. X-8. X-9.
252 Ostbye T, Krause KM, Lovelady CA, et al. Active Mothers Postpartum: a randomized controlled weight-loss intervention trial. Am J Prev Med. Sep. 2009;37(3):173-180. X-1. [pmid: 19595557].
253 Palik E, Baranyi E, Melczer Z, et al. Elevated serum acylated (biologically active) ghrelin and resistin levels associate with pregnancy-induced weight gain and insulin resistance. Diabetes Research and Clinical Practice. 2007;76(3):351-357. X-9. [pmid: 17010469].
254 Palma S, Perez-Iglesias R, Prieto D, et al. Iron but not folic acid supplementation reduces the risk of low birthweight in pregnant women without anaemia: a case-control study. J Epidemiol Community Health. Feb. 2008;62(2):120-124. X-10. [pmid: 18192599].
255 Pelaez-Crisologo MCG, Castillo-Torralba MGAGN, Festin MR. Different techniques of blood glucose monitoring in women with gestational diabetes for improving maternal and infant health [Protocol]. Cochrane Database of Systematic Reviews. 2009;4:4. X-2.
256 Perez-Chada D, Videla AJ, O’Flaherty ME, et al. Snoring, witnessed sleep apnoeas and pregnancy-induced hypertension. Acta Obstetricia et Gynecologica Scandinavica. 2007;86(7):788-792. X-7. [pmid: 17611822].
257 Peterson NB, Huang Y, Newcomb PA, et al. Childbearing recency and modifiers of premenopausal breast cancer risk. Cancer Epidemiol Biomarkers Prev. Nov. 2008;17(11):3284-3287. X-10. [pmid: 18990773].
258 Philipsen NM, Philipsen NC. Childhood overweight: prevention strategies for parents. Journal of Perinatal Education. Winter. 2008;17(1):44-47. X-1. X-2. X-3. X-7. X-8. [pmid: 19119334].
259 Picaud JC, Decullier E, Plan O, et al. Growth and bone mineralization in preterm infants fed preterm formula or standard term formula after discharge. J Pediatr. Nov. 2008;153(5):616-621. 621 e1. e2. X-1. [pmid: 18657828].
260 Pivarnik JM, Mudd L. Oh baby! Exercise during pregnancy and the postpartum period. ACSM's Health & Fitness Journal. 2009;13(3):8-13. X-2. X-3. X-7. X-8. X-9.
261 Powers GC, Ramamurthy R, Schoolfield J, et al. Postdischarge growth and development in a predominantly Hispanic, very low birth weight population. Pediatrics. Dec. 2008;122(6):1258-1265. X-1. [pmid: 19047243].
262 Puckett B, Grover VK, Holt T, et al. Cue-based feeding for preterm infants: a prospective trial. Am J Perinatol. Nov. 2008;25(10):623-628. X-1. [pmid: 18841533].
263 Pylipow M, Spector LG, Puumala SE, et al. Early postnatal weight gain, intellectual performance, and body mass index at 7 years of age in term infants with intrauterine growth restriction. J Pediatr. Feb. 2009;154(2):201-206. X-1. [pmid: 18823908].
264 Rajasingam D, Seed PT, Briley AL, et al. A prospective study of pregnancy outcome and biomarkers of oxidative stress in nulliparous obese women. Am J Obstet Gynecol. 2009;200(4):395.e1-395e9. X-10. X-11. [pmid: 19200933].
265 Ramachenderan J, Bradford J, McLean M. Maternal obesity and pregnancy complications: a review. Aust N Z J Obstet Gynaecol. Jun. 2008;48(3):228-235. X-2. X-3. X-7. X-8. [pmid: 18532950].
266 Rapaport R, Saenger P, Wajnrajch MP. Predictors of first-year growth response to a fixed-dose growth hormone treatment in children born small for gestational age: results of an open-label, multicenter trial in the United States. J Pediatr Endocrinol Metab. May. 2008;21(5):411-422. X-1. [pmid: 18655522].
267 Reader DM. Medical nutrition therapy and lifestyle interventions. Diabetes Care. 2007;30:S188-193. X-2. X-3. [pmid: 17596470].
268 Reedy NJ. Author Reply Journal of Midwifery and Women’s Health. 2008;53(1):96-97. X-2.
269 Reid SM, Middleton P, Crowther CA, et al. Interventions for clinical and subclinical hypothyroidism in pregnancy. Cochrane Database of Systematic Reviews. 2009;2:X-1. X-2. X-7. X-9.
270 Retnakaran R, Qi Y, Sermer M, et al. Isolated hyperglycemia at 1 hour on oral glucose tolerance test in pregnancy resembles gestational diabetes mellitus in predicting postpartum metabolic dysfunction. Diabetes Care. Jul. 2008;31(7):1275-1281. X-1. [pmid: 18356402].
271 Richens Y. Bring back the scales. British Journal of Midwifery. 2008;16(8):534. X-2.
272 Richens Y. Tackling maternal obesity: suggestions for midwives. British Journal of Midwifery. 2008;16(1):14-19. X-2. X-3. X-7. X-8. X-9.
273 Richens Y, Fiennes AGT. Pregnancy following bariatric surgery. British Journal of Midwifery. 2009;17(6):356-359. X-2.
274 Riedijk MA, Voortman G, van Beek RH, et al. Cyst(e)ine requirements in enterally fed very low birth weight preterm infants. Pediatrics. Mar. 2008;121(3):e561-e567. X-1. [pmid: 18283068].
275 Romo A, Carceller R, Tobajas J. Intrauterine growth retardation (IUGR): epidemiology and etiology. Pediatr Endocrinol Rev. Feb. 2009;6(Suppl 3):332-336. X-9. [pmid: 19404231].
276 Rosen R. Obesity linked to maternal deaths. Nursing Times. 2007;103(50):6-6. X-2. X-3. X-7. X-8. X-9.
277 Ruder EH, Dorgan JF, Kranz S, et al. Examining breast cancer growth and lifestyle risk factors: early life, childhood, and adolescence. Clin Breast Cancer. Aug. 2008;8(4):334-342. X-1. [pmid: 18757260].
278 Run MM, Lao TT, Chun LM, et al. Relationship between leg length and gestational diabetes mellitus in Chinese pregnant women. Diabetes Care. 2007;30(11):2960-2961. X-6. X-9. [pmid: 17666468].
279 Saha S, Loranger D, Pricolo V, et al. Feeding jejunostomy for the treatment of severe hyperemesis gravidarum: a case series. JPEN J Parenter Enteral Nutr. Sep–Oct. 2009;33(5):529-534. X-5. [pmid: 19556608].
280 Sameshima H, Kodama Y, Ikenoue T, et al. Antithrombin improves fetal condition in women with severe pre-eclampsia before 32 weeks of gestation; a randomized, double-blind, placebo-controlled trial. J Obstet Gynaecol Res. Feb. 2008;34(1):34-39. X-1. [pmid: 18226126].
281 Santos IS, Barros AJ, Matijasevich A, et al. Mothers and their pregnancies: a comparison of three population-based cohorts in Southern Brazil. Cad Saude Publica. 2008;24:S381-389. X-7. [pmid: 18797713].
282 Segal P, Hamilton JK, Sermer M, et al. Maternal obesity and familial history of diabetes have opposing effects on infant birth weight in women with mild glucose intolerance in pregnancy. J Matern Fetal Neonatal Med. Jan. 2008;21(1):73-79. X-3. [pmid: 18175247].
283 Seghieri G, Tesi F, Anichini R, et al. Influence of gestational diabetes on the long-term control of glucose tolerance. Diabetologia. 2007;50(11):2234-2238. X-2. X-9. [pmid: 17768604].
284 Semkova K, Black M. Pemphigoid gestationis: Current insights into pathogenesis and treatment. European Journal of Obstetrics Gynecology and Reproductive Biology. 2009;145(2):138-144. X-1.
285 Shapira N. Prenatal nutrition: a critical window of opportunity for mother and child. Womens Health (Lond Engl). Nov. 2008;4(6):639-656. X-2. X-3. X-7. X-8. X-9. [pmid: 19072465].
286 Shmilovich-Baram S, Rhea DJ, Keith LG, et al. The association between maternal characteristics and different types and levels of discordance in triplet pregnancies. J Perinat Med. 2008;36(2):124-128. X-1. [pmid: 18211255].
287 Siega-Riz AM, Viswanathan M, Moos MK, et al. A systematic review of outcomes of maternal weight gain according to the Institute of Medicine recommendations: birthweight, fetal growth, and postpartum weight retention, Am J Obstet Gynecol. Oct. 2009;201(4):339 e1-e14. X-2.
288 Silvani P, Camporesi A. Drug-induced pulmonary hypertension in newborns: A review. Current Vascular Pharmacology. 2007;5(2):129-133. X-1. [pmid: 17430217].
289 Simoes T, Cordeiro A, Julio C, et al. Perinatal outcome and change in body mass index in mothers of dichorionic twins: a longitudinal cohort study. Twin Res Hum Genet. Apr. 2008;11(2):219-223. X-1. [pmid: 18361724].
290 Sivasubramaniam S, Paul J. Thromboprophylaxis in pregnancy: do we need new guidelines?. Internet Journal of Anesthesiology. 2008;17(2):12-12. X-3. X-9.
291 Soares RM, Nunes MA, Schmidt MI, et al. Inappropriate eating behaviors during pregnancy: prevalence and associated factors among pregnant women attending primary care in southern Brazil. Int J Eat Disord. Jul. 2009;42(5):387-393. X-7. [pmid: 19115363].
292 Sodowski K, Zwirska-Korczala K, Kuka D, et al. Acylation stimulating protein is associated with pregnancy weight gain. J Physiol Pharmacol. Sep. 2008;59(Suppl 4):33-43. X-5. [pmid: 18955752].
293 Spellacy WN. Obstetric practice in the United States of America may contribute to the obesity epidemic. J Reprod Med. Dec. 2008;53(12):955-956. X-2. X-3. X-7. X-8. X-9. [pmid: 19160656].
294 Stotland NE. Obesity and pregnancy, BMJ. 2008;337:a2450. X-2. X-3. X-9.
295 Stotland NE. Pregnancy plus: obesity and pregnancy, BMJ: British Medical Journal. 2009;338(7686):107-110. X-2. X-3. X-7. X-8.
296 Straube S, Voigt M, Briese V, et al. Weight gain in pregnancy according to maternal height and weight. J Perinat Med. 2008;36(5):405-412. X-9. [pmid: 18601627].
297 Stuebe AM, Oken E, Gillman MW. Associations of diet and physical activity during pregnancy with risk for excessive gestational weight gain. Am J Obstet Gynecol. Jul. 2009;201(1):58 e1-e8. X-9. [pmid: 19467640].
298 Swann RA, Von Holle A, Torgersen L, et al. Attitudes toward weight gain during pregnancy: results from the Norwegian mother and child cohort study (MoBa). Int J Eat Disord. Jul. 2009;42(5):394-401. X-9. [pmid: 19115369].
299 Swanson LD, Bewtra C. Increase in normal placental weights related to increase in maternal body mass index. J Matern Fetal Neonatal Med. Feb. 2008;21(2):111-113. X-9. [pmid: 18240079].
300 Tan MJ, Cooke RW. Improving head growth in very preterm infants—a randomised controlled trial I: neonatal outcomes. Arch Dis Child Fetal Neonatal Ed. Sep. 2008;93(5):F337-341. X-1. [pmid: 18252814].
301 te Raa GD, Ribbert LS, Snijder RJ, et al. Treatment options in massive pulmonary embolism during pregnancy; a case-report and review of literature. Thromb Res. May. 2009;124(1):1-5. X-2. X-5. [pmid: 19332351].
302 Tertti K, Ekblad U, Vahlberg T, et al. Comparison of metformin and insulin in the treatment of gestational diabetes: A retrospective, case-control study. Review of Diabetic Studies. 2008;5(2):95-101. X-6. [pmid: 18795211].
303 Thomas KA, Tsai SY, Brown SN. State change in preterm infants in response to nursing caregiving: possible gender effects. Neonatal Netw. Jan–Feb. 2008;27(1):15-22. X-1. X-5. [pmid: 18232587].
304 Thornton YS. Preventing excessive weight gain during pregnancy through dietary and lifestyle counseling: a randomized controlled trial. Obstet Gynecol. Jul. 2009;114(1):173. author reply 173–174. X-2. X-3. [pmid: 19546789].
305 Tierney-Gumaer R, Reifsnider E. Risk factors for low birth weight infants of Hispanic, African American, and White women in Bexar County, Texas. Public Health Nurs. Sep–Oct. 2008;25(5):390-400. X-10. [pmid: 18816356].
306 Tieu J, Coat S, Hague W, et al. Oral anti-diabetic agents for women with pre-existing diabetes mellitus/impaired glucose tolerance or previous gestational diabetes mellitus. Cochrane Database of Systematic Reviews. 2009;2:X-2. X-7.
307 Tieu J, Crowther CA, Middleton P. Dietary advice in pregnancy for preventing gestational diabetes mellitus. Cochrane Database of Systematic Reviews. 2008;2:X-9.
308 Tieu J, Crowther CA, Middleton P, et al. Screening for gestational diabetes mellitus for improving maternal and infant health. Cochrane Database of Systematic Reviews. 2008;3:X-2.
309 Tieu J, Middleton P, Crowther CA. Preconception care for diabetic women to improve maternal and infant health [Protocol]. Cochrane Database of Systematic Reviews. 2009;4:4. X-2.
310 Tinoco SM, Sichieri R, Setta CL, et al. n-3 polyunsaturated fatty acids in milk is associate to weight gain and growth in premature infants. Lipids Health Dis. 2009;8(23):X-1-X-5.
311 To WW, Wong MW. Body fat composition and weight changes during pregnancy and 6–8 months post-partum in primiparous and multiparous women. Aust N Z J Obstet Gynaecol. Feb. 2009;49(1):34-38. X-10. [pmid: 19281577].
312 Torre P, Ladaki C, Scire G, et al. Catch-up growth in body mass index is associated neither with reduced insulin sensitivity nor with altered lipid profile in children born small for gestational age. J Endocrinol Invest. Sep. 2008;31(9):760-764. X-1. [pmid: 18997486].
313 Toschke AM, von Kries R, Beyerlein A, et al. Risk factors for childhood obesity: shift of the entire BMI distribution vs. shift of the upper tail only in a cross sectional study. BMC Public Health. 2008;8:115. X-1. [pmid: 18402677].
314 Troisi R, Lagiou P, Trichopoulos D, et al. Cord serum estrogens, androgens, insulin-like growth factor-I, and insulin-like growth factor binding protein-3 in Chinese and U.S. Caucasian neonates. Cancer Epidemiol Biomarkers Prev. Jan. 2008;17(1):224-231. X-1. X-9. [pmid: 18199728].
315 Underwood MA, Salzman NH, Bennett SH, et al. A randomized placebo-controlled comparison of 2 prebiotic/probiotic combinations in preterm infants: impact on weight gain, intestinal microbiota, and fecal short-chain fatty acids. J Pediatr Gastroenterol Nutr. Feb. 2009;48(2):216-225. X-1. [pmid: 19179885].
316 Valieva OA, Strandjord TP, Mayock DE, et al. Effects of transfusions in extremely low birth weight infants: a retrospective study. J Pediatr. Sep. 2009;155(3):331-337. e1. X-1. [pmid: 19732577].
317 Valuniene M, Verkauskiene R, Boguszewski M, et al. Leptin levels at birth and in early postnatal life in small- and appropriate-for-gestational-age infants. Medicina (Kaunas). 2007;43(10):784-791. X-1. [pmid: 17998795].
318 Veerareddy S, Khalil A, O’Brien P. Obesity: implications for labour and puerperium. British Journal of Midwifery. 2009;17(6):360-362. X-2. X-3. X-7. X-8.
319 Velez MP, Santos IS, Matijasevich A, et al. Maternal low birth weight and adverse perinatal outcomes: the 1982 Pelotas Birth Cohort Study, Brazil. Rev Panam Salud Publica. Aug. 2009;26(2):112-119. X-3. X-7. [pmid: 19814890].
320 Vitoratos N, Valsamakis G, Mastorakos G, et al. Pre- and early post-partum adiponectin and interleukin-1beta levels in women with and without gestational diabetes. Hormones (Athens). Jul–Sep. 2008;7(3):230-236. X-6. [pmid: 18694861].
321 Voldner N, Froslie KF, Bo K, et al. Modifiable determinants of fetal macrosomia: role of lifestyle-related factors. Acta Obstet Gynecol Scand. 2008;87(4):423-429. X-10. [pmid: 18382868].
322 Von Tempelhoff GF, Velten E, Yilmaz A, et al. Blood rheology at term in normal pregnancy and in patients with adverse outcome events. Clinical Hemorheology and Microcirculation. 2009;42(2):127-139. X-10. [pmid: 19433886].
323 Walker LO. Low-income women's reproductive weight patterns empirically based clusters of prepregnant, gestational, and postpartum weights. Womens Health Issues. Nov–Dec. 2009;19(6):398-405. X-9. [pmid: 19766016].
324 Wallis J. Research round-up. RCM Midwives. 2007;10(10):456-456. X-2.
325 Ward S, Wisner KL. Collaborative Management of Women with Bipolar Disorder During Pregnancy and Postpartum: Pharmacologic Considerations. Journal of Midwifery and Women’s Health. 2007;52(1):3-13. X-1.
326 Wax JR, Cartin A, Wolff R, et al. Pregnancy following gastric bypass for morbid obesity: effect of surgery-to-conception interval on maternal and neonatal outcomes. Obes Surg. Dec. 2008;18(12):1517-1521. X-1. X-5. [pmid: 18685903].
327 Weintraub V, Mimouni FB, Dollberg S. Effect of birth weight and postnatal age upon resting energy expenditure in preterm infants. Am J Perinatol. Mar. 2009;26(3):173-177. X-1. [pmid: 19021091].
328 Wendland EM, Duncan BB, Belizan JM, et al. Gestational diabetes and pre-eclampsia: common antecedents. Arq Bras Endocrinol Metabol. Aug. 2008;52(6):975-984. X-6. X-7. [pmid: 18820808].
329 Windham G, Fenster L. Environmental contaminants and pregnancy outcomes. Fertil Steril. Feb. 2008;89(2 Suppl):e111-e116. discussion e117. X-1. [pmid: 18308050].
330 Wisner KL, Sit DK, Hanusa BH, et al. Major depression and antidepressant treatment: impact on pregnancy and neonatal outcomes. Am J Psychiatry. May. 2009;166(5):557-566. X-6. [pmid: 19289451].
331 Worobey J, Islas-Lopez M, Hoffman DJ. Predictors of infant feeding frequency by Mexican immigrant mothers. Topics in Clinical Nutrition. 2008;23(4):333-339. X-1. X-7. [pmid: 19584950].
332 Yogev Y, Catalano PM. Pregnancy and obesity. Obstet Gynecol Clin North Am. Jun. 2009;36(2):285-300. viii. X-2. X-3. X-7. X-8. X-9. [pmid: 19501314].
333 Zeng L, Dibley MJ, Cheng Y, et al. Impact of micronutrient supplementation during pregnancy on birth weight, duration of gestation, and perinatal mortality in rural western China: double blind cluster randomised controlled trial BMJ. 2008;337:a2001. X-1. X-7.