# List of Ongoing Studies

Title (project number) | Description | Comments | Principal Investigator | Organization
Limiting weight gain in overweight pregnant women: effects on mother and child (5R01HL094235-03) | Maternal obesity entering pregnancy and excessive gestational weight gain produce substantial morbidity, and both have been rising in prevalence in the past 2 decades. Researchers at the University of Adelaide, Australia, are now funded to begin the largest-by a factor of 10-RCT to limit gestational weight gain among overweight and obese women. The trial will involve state-of-the-art diet and physical activity intervention components to limit weight gain during pregnancy to 0 to 5 kg among a diverse population of 2500 pregnant women. The trial is powered to detect important maternal and infant morbid outcomes based on routinely collected clinical data. Unfortunately, the funding for this trial is not sufficient to collect data on body composition and cardio-metabolic outcomes for mother and child. Yet these biomarker data would be invaluable in elucidating physiologic pathways by which the intervention has its effects, in determining the intervention effect on intermediate maternal outcomes, and perhaps most importantly for the long-term, investigating effects on body composition and cardio-metabolic outcomes among the offspring. The overall goal of this proposal is to assess the effects of an intervention to limit excessive gestational weight gain among overweight and obese pregnant women on markers of adiposity and cardio-metabolic risk in mother, fetus, and newborn. Outcome measures will include Mother: At 28 weeks' gestation, estimated insulin resistance, glucose tolerance, and levels of triglycerides, leptin, adiponectin, and C-reactive protein. Fetus: Change in estimated fetal weight from 18–28 and 28–36 weeks. Newborn: Body fat by air displacement plethysmography and skinfold thicknesses, and cord blood levels of leptin and adiponectin. This proposal reflects a new interdisciplinary collaboration between researchers at Harvard Medical School and the University of Adelaide, with combined expertise in RCTs involving behavior change and in pregnancy, numerous studies of pregnant women and their offspring, and measurement and interpretation of body composition, physiologic, and cardio-metabolic data in mother and child. By obtaining the data from this ancillary study, the trial will be set up not only to provide answers to the proposed aims, but also-with additional funding for followup and to take advantage of the stored biosamples-to address numerous questions on long-term health of the mother and the growing child. Limiting excess weight gain during pregnancy among overweight and obese women could help prevent serious health consequences in the mother and child, and a large 4-year randomized controlled trial will begin in mid- 2008 to test this theory. As an ancillary study to the parent trial, the proposed project will add crucial information about the physiology of the mother, the growth of the fetus, and the body composition of the newborn baby. This study will repay its investment many times over by examining how and how well the parent trial works, and by setting up a biological resource that scientists could use to address additional key questions about long-term health of the mothers and children. | National Heart, Lung, and Blood Institute (NHLBI) Funding: $309,415 For more details, see http://projectreporter.nih.gov/project_info_description.cfm?aid=7885660&icde=5088205 | Gillman, Matthew W | Harvard Pilgrim Health Care, Inc.
GWA mapping: maternal metabolism-birth weight interactions (3U01HG004415-02S1) | Low and high birth weights are a major cause of neonatal morbidity and mortality, and epidemiological data have established an association between birth weight and later risk of adult metabolic disease. Fetal growth is determined by complex interactions between fetal genes and the maternal uterine environment. Subtle or overt variation in maternal glucose tolerance which is, in part, genetically determined, is related to fetal size at birth. New emerging data suggest that genetic variation in the fetus can impact maternal metabolism. Given the above, we are hypothesizing that during pregnancy, gene-environment interactions in the context of the maternal-fetal unit impact fetal size at birth and maternal metabolism. To address this hypothesis, we are proposing to perform genome wide association (GWA) mapping on a subset of ~37,000 DNA samples that were collected from mothers and their offspring as part of the NIH-funded Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study. HAPO is a multicenter, international study in which high quality phenotypic data related to fetal growth and maternal glucose metabolism has been collected from 25,000 pregnant women of varied racial and sociodemographic backgrounds using standardized protocols that were uniform across centers. We are proposing to genotype 1,500 infants and their mothers of European descent to accomplish the following specific aims: (1) To apply analytic approaches for conducting GWA mapping studies on quantitative phenotypes related to offspring size at birth (birth weight, ponderal index, head circumference and adiposity) allowing for other known influences such as gestational age, parity, and maternal weight gain. (2) To apply the above approaches to identify genetic variation that impacts maternal glucose tolerance at ~28 weeks of gestation (fasting glucose, glucose during an oral glucose tolerance test, and insulin sensitivity expressed as quantitative traits) allowing for other known influences such as maternal weight gain, parity and age. (3) To examine the interaction between maternal genes, the intrauterine environment, and fetal genes to identify interactions that modulate genetic regulation of size at birth and fetal genetic variation that impacts on maternal glucose tolerance. A replication study will be performed in additional infants and mothers of European descent with followup studies also planned in Afro-Caribbeans, Hispanics of Mexican descent and Thais. | National Human Genome Research Institute Funding: $65,044 For more details, see http://projectreporter.nih.gov/project_info_description.cfm?aid=7923473&icde=5088205 | Lowe, William L | Northwestern University
Maternal overweight: consequences for insulin signaling in the offspring (5R01DK084225-02) | The major reasons underlying the remarkable global rise in obesity remain unclear. While, diet composition and life-style factors such as physical activity undoubtedly have important roles in determining body composition, maternal overweight (OW) status (BMI > 25) at conception may be a critical synergizing factor. In clinical studies, we found that maternal OW status significantly increased risk of OW (i.e. the % above the 95th percentile) at 6 months of age, in infants born with normal body weights. Our overall objective is to investigate interactions in the offspring, between an obesegenic environment (consumption of a high-fat diet, HFD) and prior exposure to maternal OW during gestation. To this end, we have developed a rat model in which metabolic and endocrine abnormalities akin to obesity in human subjects were reproduced prior to conception. Exposure to maternal OW did not influence birth weight/size of offspring. However, offspring from OW dams when fed a HFD became obese to much greater extent compared to offspring from lean dams on the same diet, without changes in caloric intake. Offspring of OW rats also developed hyperinsulinemia, adipose tissue hypertrophy and showed lipogenic gene expression. Based on our preliminary studies, we hypothesize that increased glucose flux into adipose tissue and accelerated lipogenesis causes obesity in the offspring of OW dams when fed a HFD. The proposed studies are aimed at understanding the underlying differences in energy balance and insulin signaling prior to the development of obesity in the offspring. In Specific Aim 1, indirect calorimetry will be utilized to examine if gestational OW decreases energy expenditure in the offspring. In Specific Aim 2, we will test the hypothesis that maternal OW leads to skeletal muscle insulin resistance in the offspring, consequently increasing glucose partitioning into adipose tissue, lipogenesis and fat mass accretion. This will be addressed via hyperinsulinemic-euglycemic clamp experiments using labeled tracers, and will reveal the status of insulin sensitivity in the individual tissues (skeletal muscle, adipose and liver) and whole-body glucose flux. Studies examining responsiveness of adipose tissue to insulin signaling via IR-PI3K-Akt to increase lipogenic gene expression and de novo lipid synthesis and will be performed in Specific Aim 3. Finally, Specific Aim 4 will employ physical activity prior to conception as an intervention and will test the hypothesis that increased physical activity (treadmill running) in the OW dams prior to conception will improve offspring insulin sensitivity and mitigate increased adipose tissue anabolism. Overall, these studies will elucidate important metabolic mechanisms in the offspring altered by maternal OW and high-fat diets, which may contribute to increased susceptibility to obesity. PUBLIC HEALTH RELEVANCE: Maternal overweight (OW) during pregnancy significantly increases the risk of OW in the offspring. While, the underlying reasons remain unclear, using a new model of maternal OW in the rat, we have identified that, post-natal high-fat diets significantly exacerbate development of obesity in offspring of OW rats. We will examine changes in glucose flux and the synthesis of fat in the adipose tissues of OW offspring. These mechanisms may underlie the predisposition of the offspring to gain more fat relative to muscle mass, leading to obesity. These studies will elucidate mechanisms that are altered in the offspring due to maternal OW and provide novel opportunities for intervention and prevention of obesity. | National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK) Funding: $349,272 For more details, see http://projectreporter.nih.gov/project_info_description.cfm?aid=7880140&icde=5088205 | Shanar, Kartik | Arkansas Children’s Hospital Research Institute
Limiting the phenotypic effect of pregnancy related weight gain (5K23NR010748-02) | This program of research focuses on obesity in women, with an emphasis on the genetic effects on weight gain, especially in the vulnerable time of pregnancy and interventions to prevent and/or limit excessive pregnancy weight gain. The intermediate goals of this career development plan focus on education and research. The educational goal is to acquire skills central to test gene-environment interactions and the implementation of intervention studies in the context of an interdisciplinary team in preparation for a full scale R01. The research goal is to develop expertise as an independent investigator by implementing two projects to develop expertise as an independent involving (a) clarification of the gene-environment interaction of the GNB3 gene and (b) focus groups to elicit the attitudes and beliefs of African-American women about physical activity during pregnancy. The findings will provide a framework for the establishing a foundation for genetic-based behavioral intervention research. These goals are the direct result of the candidate's experiences as a women's health nurse practitioner coupled with training at the NINR summer genetics institute in 2006. Practice as a clinician providing health care to underserved and uninsured women since 1994 has extensively influenced my research goals. This proposed career development plan pulls together discrete areas of research that require very different skill sets. Therefore, an interdisciplinary team of mentors and consultants, with distinct areas of expertise, have been included in this career development team. Environment: The University of Rochester, School of Nursing, a part of the University of Rochester Medical Center, has a long history of nursing research. In 2006 the University of Rochester received a $40 million NIH award to establish a Clinical and Translational Science Institute (CTSI), which has increased support to researchers across the medical center and created an atmosphere conducive to collaborative and interdisciplinary teams for translational research from T1–T4. The candidate received funding from the CTSI for a KL2 scholar award in July 2008, which provides bridging funding for 1–2 years until individual funding can be attained. Given the supportive environment, the early stages of this career development plan recently began under the guidance of this team of experienced NIH funded, nationally recognized mentors, who provide an essential combination of expertise for the identified areas of development: expertise in research design including RCTs and focus groups, cultural competency and recruiting of vulnerable populations, genetics, and exercise in pregnancy. Research: Recent figures indicate three-quarters of all African-American women are overweight or obese. Obesity in African-American women is due, in part, to excessive pregnancy weight gain. Genetic susceptibility and individual behaviors likely interact and contribute to pregnancy weight gain, which then contributes to long-term obesity. Thus, prevention of excessive gestational weight gain would decrease morbidity and mortality in US African-American women. Little is known about gene-environment interactions that contribute to pregnancy weight gain. Seventy percent of the world-wide African-American population carries the GNB3 825T allele, which appears to be associated with increased gestational weight gain, postpartum weight retention, and low birth weight. It is postulated that African-American women who gain and retain excessive pregnancy weight and deliver smaller infants are carriers of the 825T allele—an effect that may be attenuated by physical activity. The overarching goal of this proposal is to establish the foundation to develop, test, and implement a physical activity intervention in high-risk African American women using the essential amount of physical activity, based on genotype, required to limit excessive weight gain/retention in pregnancy. To this end, the research plan has 3 aims: (a) examine the GNB3 825T allele gene-environment interaction during pregnancy; (b) determine the critical levels of physical activity essential to prevent excessive weight gain for women who carry the 825T allele; and (c) identify women's beliefs regarding physical activity during pregnancy and what physical activities African-American women would participate in while pregnant. To accomplish these goals two projects will be conducted: (1) Phase I study—a prospective candidate gene-association study examining the GNB3 825T allele and how it interacts with physical activity during pregnancy and (2) Phase II study—a qualitative, descriptive study that utilizes focus groups to elicit the attitudes and beliefs of African-American women regarding physical activity during pregnancy. The Phase I study, utilizing established interviews and questionnaires for dietary and physical activity measurement, pedometers, weight/height measurement, resting energy expenditure measures, and deoxyribonucleic acid (DNA) was approved by the University of Rochester Research Subjects Review Board. The protocol and procedures are in place and active recruitment has recently commenced. PUBLIC HEALTH RELEVANCE: Obesity in US women, especially African-American women is due, in part, to excessive pregnancy weight gain. Genetic susceptibility and individual behaviors likely interact and contribute to pregnancy weight gain, which then contributes to obesity. Prevention of excessive gestational weight gain would decrease morbidity and mortality in US African-American women. | National Institute of Nursing Research FY total funding: $130,130 For more details, see http://projectreporter.nih.gov/project_info_description.cfm?aid=7942760&icde=5092019 | Groth, Susan W | University of Rochester
Maternal overnutrition and offspring fat mass, metabolic and vascular function (5R01DK077659-04) | We propose to study the effects of maternal obesity, weight gain and diet during pregnancy on offspring fat mass, fat distribution, vascular and metabolic function. Specifically we will: 1. Determine the magnitudes of the associations of maternal BMI, weight gain and diet during pregnancy with offspring adiposity (DXA assessed fat mass and fat distribution), vascular function (blood pressure, pulse pressure and endothelial function) and metabolic function (fasting glucose, insulin and lipids). 2. Determine whether any association between maternal factors and offspring outcomes represent a specific intrauterine effect by comparing the maternal-offspring associations to equivalent paternal-offspring associations. 3. Examine the role of intrauterine growth, offspring nutrition and physical activity in explaining the associations of maternal obesity, weight gain and diet during pregnancy with offspring obesity, metabolic and vascular function. These aims and objectives will be achieved using data from a large, population-based cohort of children recruited before birth and followed up to the present day. The study - the Avon Longitudinal Study of Parents and Children (ALSPAC) - recruited 14,541 pregnant women in 1991–92. Of these 13,617 women delivered a live singleton child who was still alive at one year after birth. Of these singleton births we have measurements of offspring outcomes: fat mass and fat distribution determined by Dual Emission X-Ray Absorptiometry (DXA), blood pressure, endothelial function determined by high-resolution ultrasound imaging and metabolic function determined by fasting glucose, insulin and lipids up to age 15 years on over 7,000. Further, DNA has been extracted on both mothers and their offspring. A large amount of data has been collected on both parents, including their weight and height and diet in pregnancy. This work will make an important contribution to our understanding of the developmental origins of obesity and its associated vascular and metabolic abnormalities. It will provide the necessary evidence for the development of randomised controlled trials concerned with examining the effectiveness of brief interventions during the intrauterine period (a key developmental period for obesity) in the prevention of future obesity. | NIDDK FY total funding: $237,097 For more details, see http://projectreporter.nih.gov/project_info_description.cfm?aid=7686755&icde=5092019 | Lawlor, Debbie Anne | University of Bristol
Weight management for improved pregnancy outcomes (3R01HD058061- 01A1S1) | Historically, under nutrition has been a major health concern. Recently however, over nutrition has also become a serious public health problem in the United States and other industrialized countries. With the new obesity epidemic we see increasing morbidity, mortality, and public health burden, particularly among reproductive-aged women. Whereas morbid obesity was once rare among pregnant women, a rapidly increasing proportion of obstetrics patients now have levels of obesity which dramatically increase their risk of serious pregnancy complications. These complications include increased risk of miscarriage, stillbirth, having a fetus that is too large leading to cesarean section or birth injuries for mom and baby from vaginal delivery, and death of the infant in the newborn period. More than 1/3 of women in the U.S. are now starting their pregnancies with a body mass index or 30 or greater, a condition that was unusual to rare 50 years ago. Given the serious consequences of added weight gain during pregnancy for obese women, such as gestational diabetes, preeclampsia, or cesarean delivery, the best strategy during their pregnancy may be to maintain a steady weight rather than gaining 15 pounds or more. Unfortunately, there is little research on the efficacy and feasibility of minimizing weight gain during pregnancy. This study is designed to address that problem. Two hundred women with BMIs of 30 or greater at the start of their pregnancy will be recruited for this feasibility test. All participants will be members of a non-profit managed care organization that provides high-quality obstetrics care. Patients who volunteer to participate will be randomly assigned to either a weight maintenance intervention or to usual care. Participants assigned to the intervention will participate in a weight maintenance program designed to help them eat a nutritionally balanced diet and to also control energy intake to minimize weight gain during their pregnancy. Participants (and their babies) in both groups will participate in followup assessments at 2 weeks postpartum, 6 months postpartum and one year postpartum. The primary outcome measures will be mothers' weight gain during pregnancy, the amount of weight retained after delivery, and the proportion of large for gestational age infants. Secondary outcomes will include multiple safety measures of the mothers and their babies. In addition to measures of safety, our secondary analyses will address the feasibility and acceptability of a weight management intervention among obese pregnant women. | Eunice Kennedy Shriver National Institute of Child Health & Human Development Funding: $26,825 For more details, see http://projectreporter.nih.gov/project_info_description.cfm?aid=8007523&icde=5092019 | Stevens, Victor J | Kaiser Foundation Research Institute