# Search Strategy for Ongoing Studies

www.clinicaltrials.gov:

maternal weight gain [=47 studies]

gestational weight gain [=33 studies]

(maternal OR gestational OR pregnancy OR pregnant) AND (weight gain OR overweight OR obesity) [=147 studies]

# Citations: 20 selected for database

NIH RePORTER:

maternal weight gain [=84 studies]

gestational weight gain [=49 studies]

# Citations: X in table above

www.controlled-trials.com: (includes coverage of UK/European trials information)

(maternal OR pregnancy OR pregnant OR gestational) AND weight [=40 studies]

(maternal OR pregnancy OR pregnant OR gestational) AND (weight OR overweight OR obese OR obesity) [=40 studies]

# Citations: none appear relevant to topic