# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BMI: Body mass index
BRFSS: Behavioral Risk Factor Surveillance System
CER: Comparative Effectiveness Reviews
CMTP: Center for Medical Technology Policy
EHC: Effective Health Care
EPC: Evidence-based Practice Center
GWG: Gestational weight gain
IOM: Institute of Medicine
kg: Kilogram(s)
KQ: Key question
LGA: Large-for-gestational age
PICO: Population, Intervention, Comparator, Outcome
PRAMS: Pregnancy Risk Assessment Monitoring System
SER: Systematic evidence review
SGA: Small-for-gestational age
SR: Systematic review
WG: Weight gain
WIC: Women, Infants, and Children