# Results

## Stakeholders

Twenty-two of 40 stakeholders (55%), representing consumer advocates and policymakers (9), and clinicians, research funders, and researchers (12, including 3 federal employees), (Table 1) agreed to participate, and 21 of 40 invited completed the questionnaire (53%).

Table 1 Participants and organizations

Stakeholders | Total Invited | Participated | Percent Participation | Participating Organizations And Individuals
Consumer Advocates | 10 | 6 | 60% | Breast Cancer Action, Susan G. Komen Foundation, Northwest Portland Indian Health Board, Our Bodies Ourselves, Young Survival Coalition, and National Partnership for Women and Families
Policymakers | 7 | 2 | 29% | American College of Obstetricians and Gynecologists, AHRQ
Clinicians | 8 | 4 | 50% | Family physician, naturopathic physician, breast cancer surgeons (2)
Research Funders | 6 | 4 | 67% | National Cancer Institute (2), National Institutes of Health, Office of Research in Women’s Health, and American Cancer Society
Researchers | 9 | 5 | 56% | University/ Academic Medical Centers (4) and the National Comprehensive Cancer Network
Total | 40 | 21 | 53%

Research funders (67%) were most likely to participate of all stakeholders, while policymakers were least likely to participate (29%). Among consumer advocates, researchers, and clinicians, 60%, 56%, and 50%, respectively, participated. Participants were not substantially different from non-participants. Ultimately, of the 21 stakeholders, 29% were consumer advocates, 24% researchers, 19% clinicians, 19% research funders, and 9% policymakers (Figure 3).

Figure 3 Recruitment and participation

This flowchart gives details of the process—and results—of inviting individuals and organizations to participate in a Webinar and questionnaire on “Developing a Future Research Agenda to Reduce the Risk of Primary Breast Cancer in Women.” Of 40 individuals and organizations invited to participate, 22 agreed. Of these, 17 attended the Webinar and were sent a questionnaire, and 5 were sent a taped Webinar and questionnaire. A total of 21 questionnaires were completed (95%). Of these, 9 completed Questionnaire I (for consumers/policymakers), and 12 completed Questionnaire II (for clinicians/research funders/researchers).

Reasons for refusal included: not interested in the project (2), unavailable due to a vacation/schedule conflict (7) and one clinician declined because the employer, a federal organization, does not allow participation in research (Figure 3).

Also shown in Figure 3, stakeholders varied in their preference for questionnaire completion. Three stakeholders initially submitted incomplete questionnaires and were contacted by the study team to review and to complete missing sections. Reasons for incomplete questionnaires were technical difficulties (trouble with internet connection) and accidental omission of a section of the PDF questionnaire. One-third of the stakeholders completed the questionnaire in more than one sitting.

Stakeholders were asked to self report their perspective(s) and these were compared to the primary perspectives assigned by the research team (Table 2). Among respondents, stakeholder perspectives were correctly assigned by the research team in 20 of 21 cases (95%). The one discrepancy was a member of a policymaking body that self-identified as clinician, research funder, and researcher. Interestingly, 38 percent of stakeholders reported that they were responding from multiple perspectives.

Table 2 Team-assigned and self-identified perspectives of stakeholders

Respondent | Perspective Assigned | Perspective Chosen
1 | Clinician | Clinician, Consumer Advocate
2 | Clinician | Clinician
3 | Clinician | Clinician
4 | Clinician | Clinician
5 | Clinician | Clinician
6 | Consumer Advocate | Consumer Advocate
7 | Consumer Advocate | Consumer Advocate, Clinician
8 | Consumer Advocate | Consumer Advocate
9 | Consumer Advocate | Consumer Advocate
10 | Consumer Advocate | Consumer Advocate
11 | Consumer Advocate | Consumer Advocate
12 | Policymaker | Clinician, Research Funder, Researcher
13 | Policymaker | Clinician, Policymaker
14 | Policymaker | Clinician, Researcher
15 | Research Funder | Clinician, Research Funder, Researcher
16 | Research Funder | Research Funder
17 | Research Funder | Clinician, Research Funder, Researcher Policymaker
18 | Researcher | Researcher
19 | Researcher | Researcher, Clinician
20 | Researcher | Researcher
21 | Researcher | Researcher

## Research Priorities

Two distinct methods were used to obtain future research ideas and priorities: (1) an open-ended question asking stakeholders to write in at least three questions that they thought were highest priority for research and (2) prioritization and comments from structured questions. Frequencies with which each item was listed as high priority were calculated and items presented from highest to lowest frequency.

### Research Priorities According To Open-Ended Questions

Stakeholders were asked, “What do you believe are the most important research questions in preventing breast cancer?” This question was intentionally asked prior to the itemized listing to acquire the initial impressions of stakeholders. Table 3 summarizes narrative themes by questionnaire group.

Table 3 Research priorities from open-ended questions

Questionnaire I: Consumer/Policymaker | Questionnaire II: Clinician/Research Funder/Researcher
Population | Population
1. What group is at highest risk for breast cancer?; a. Race/ethnicity/community/exposures/genetics/menopausal status; 2. What group is most likely to benefit from treatment?; a. Genetics; 3. Risk assessment tools; a. Accuracy; b. Tailored to racial/ethnic groups; c. Tailored to individual conditions; 4. Distribution of receptor types among racial/ethnic minorities, as well as within subgroups | 1. What group is at highest risk for breast cancer?; a. Biomarkers; 2. What group is most likely to benefit from medical over lifestyle treatment?; a. Genetics; b. Biomarkers; c. More than just ER status (ER tumors are heterogenous); 3. Risk assessment tools; a. More accurately predict risk; b. More accurately predict who is likely to benefit from treatment; c. Tailored to racial ethnic groups; d. Including molecular/genetic biomarkers; e. Tailored to individual conditions; 4. How can we prevent ER-negative breast cancer?
Intervention | Intervention
1. Interventions suggested; a. Behavioral; b. Environmental; c. Ingestible substances; d. Specific recommendations (Indian diet); 2. Best timing in breast cancer life cycle for intervention; 3. Interventions targeting; a. Highest risk; b. Aggressive and lethal types of breast cancer; c. ER-negative breast cancer; 4. What substances ingested by women (in food, air, water) increase the risk of breast cancer? | 1. Identifying more effective medications to reduce the risk of breast cancer; 2. Interventions suggested; a. Fish oil; b. DIM; c. Green tea; d. Diet/weight control; e. Vegetables (type & amount); f. Fruit (type & amount); g. Lifestyle; i. Exercise; ii. Stress management; h. Metformin; i. Aromatase inhibitors; 3. Studying specific interventions in specific populations (effect of diet, exercise, and weight control on breast cancer risk among African American and Hispanic women); 4. Intervention studies need to bank serum for biomarkers/cytokines to understand response and for potential monitoring
Comparators | Comparators
None | 1. Diet/lifestyle modifications vs. medications; a. Tamoxifen/aromatase vs. lifestyle vs. combined; b. What groups more likely to benefit from each
Outcomes | Outcomes
1. Long-term followup; a. Is cancer ‘prevented’ or delayed?; b. Harms - what are the long-term effects of taking raloxifene for 10 or more years?; 2. Target more aggressive types of breast cancer | 1. Long-term followup; a. Efficacy for tamoxifen and raloxifene; 2. Molecular/genetic predictors of response to treatment; a. Understanding phenotype of responders vs. nonresponders; b. Biomarkers to shorten clinical trials time; 3. Screening/surveillance intervals; 4. Risk/benefit ratio of treatments
Influencing Factors | Influencing Factors
1. Decisionmaking; a. Patient - how do women weigh the benefits/harms of chemoprophylaxis?; b. Provider - how can providers best support a person’s decisionmaking process?; c. Who is considering preventive care?; d. Tailored to race/ethnic background; 2. Education; a. How can we ensure the provider is up to date on the latest research?; 3. Communication; a. How providers communicate information in a way patients understand?; b. What opportunities are important for patients to ask questions for information, guidance and support?; c. What is best method to communicate risks?; 4. Influences; a. Differences in systems of care (increased coverage of prevention activities from health plans); b. What factors influence a women's decision to use chemoprophylaxis? | 1. Decisionmaking; a. Tools to improve decisionmaking and communication; b. Individualized risks; 2. Education; a. Better strategies to disseminate information (especially aromatase inhibitors); b. How can we ensure the provider is up to date on the latest research?; c. How can we ensure the patient is up-to- date on the latest research?; 3. Compliance; a. Patient - understanding why more patients do not use SERMs; b. Provider - barriers for physicians prescribing SERMs; 4. Influences; a. Social; b. Economic; c. Medical barriers preventing high-risk women from using chemopreventive agents

Abbreviations: ER=estrogen receptor; DIM=diindolylmethane; SERM=selective estrogen receptor modulator.

While all stakeholders agreed that a priority for future research should be placed on understanding which populations are at highest risk for breast cancer and which are most likely to benefit from preventive therapies, consumers and policymakers focused on demographic factors such as age, race, and ethnicity. Researchers and funders, on the other hand, focused on examining risk based upon genetics and biomarkers. As a whole, stakeholders consistently were highly interested in non-medical interventions such as lifestyle changes including diet, and exercise, with clinicians, funders, and researchers wanting not only more information on the effectiveness of individual changes but also direct comparisons of medical vs. non-medical (e.g., lifestyle) treatments. Similarly, both stakeholder groups thought research is needed to identify and evaluate methods to ensure that providers were up to date in their knowledge and to promote decisionmaking. Compared with researchers, clinicians, and funders, consumers and policymakers were more likely to want additional research on patient-provider communication strategies and how to communicate risks to patients.

### Research Priorities According to Structured Questions

Table 4 details responses for each questionnaire question by stakeholder group.

Table 4 Detailed responses to structured priority questions

Consumer/Policymaker Question | High (%) (n) | Medium (%) (n) | Low (%) (n) | Clinician/Research Funder/Researcher Question | High (%) (n) | Medium (%) (n) | Low (%) (n)
Population | | | | Population
Q5. Studies of how age affects the benefits and/or harms of interventions to reduce the risk of breast cancer. | 44.4% (4) | 55.6% (5) | 0 (0) | Q4. Studies to understand the differences of benefits and/or adverse effects by age. | 50.0% (6) | 25.0% (3) | 25.0% (3)
Q6. Studies of how race and/or ethnicity affect the interventions to reduce the risk of breast cancer. | 66.7% (6) | 33.3% (3) | 0 (0) | Q5. Studies to understand the differences of benefits and/or adverse effects by race and/or ethnicity. | 33.3% (4) | 33.3% (4) | 33.3% (4)
Q7. Studies to understand which populations of women would optimally benefit from medications to reduce their risk of breast cancer. | 77.8% (7) | 11.1% (1) | 11.1% (1) | Q6. Studies to understand which populations of women would optimally benefit from medications to reduce their risk of breast cancer. Please include recommendations (i.e., study types, populations). | 75.0% (9) | 16.7% (2) | 8.3% (1)
Intervention/Comparators (Comparisons) | | | | Intervention/Comparators (Comparisons)
Q8. Prescription medications: Tamoxifen, Raloxifene | 50.0% (4) | 50.0% (4) | 0 (0) | Q9. Tamoxifen citrate and raloxifene (SERMs: Selective Estrogen Receptor Modulators) | 54.5% (6) | 18.2% (2) | 27.3% (3)
Q9. Prescription medication: Tibolone (this medication is not currently approved in the US) | 25.0% (2) | 62.5% (5) | 12.5% (1) | Q7. Tibolone (STEAR: Selective Tissue Estrogenic Activity Regulator) | 20.0% (2) | 40.0% (4) | 40.0% (4)
Q10. Vitamin A derived medications (e.g. retinols) | 42.9% (3) | 42.9% (3) | 14.3% (1) | (Question not asked of Clinician/Research funder/Researcher)
(Question not asked of Consumer/Policymaker) | | | | Q8. Aromatase inhibitors | 54.5% (6) | 9.1% (1) | 36.4% (4)
Q11. Drugs based on a person's genetics | 37.5% (3) | 50.0% (4) | 12.5% (1) | Q12. Gene-based drugs | 54.5% (6) | 9.1% (1) | 36.4% (4)
Q12. Drugs that target specific molecular cancer pathways | 62.5% (5) | 37.5% (3) | 0 (0) | Q13. Molecularly targeted agents | 40.0% (4) | 50.0% (5) | 10.0% (1)
Q13. Complementary and alternative therapies | 66.7% (6) | 33.3% (3) | 0 (0) | Q10. Complementary and alternative therapies | 36.4% (4) | 9.1% (1) | 54.5% (6)
Q15. Weight loss as therapy | 22.2% (2) | 44.4% (4) | 33.3% (3) | Q14. Weight loss as therapy | 50.0% (6) | 16.7% (2) | 33.3% (4)
Q16. Exercise as therapy | 33.3% (3) | 44.4% (4) | 22.2% (2) | Q15. Exercise as therapy | 50.0% (6) | 16.7% (2) | 33.3% (4)
Q17. Diet as therapy | 22.2% (2) | 55.6% (5) | 22.2% (2) | Q16. Diet as therapy | 50.0% (6) | 25.0% (3) | 25.0% (3)
Q19. Combination therapies (e.g., aspirin + prescription medication) | 50.0% (3) | 33.3% (2) | 16.7% (1) | Q18. Combination therapies (e.g., aspirin + tamoxifen) | 27.3% (3) | 36.4% (4) | 36.4% (4)
Q20. Other lifestyle modifications | 37.5% (3) | 50.0% (4) | 12.5% (1) | Q20. Other lifestyle modifications | 16.7% (2) | 33.3% (4) | 50.0% (6)
Outcomes | | | | Outcomes
Q24. Reporting all harmful effects of medications prescribed to reduce breast cancer risk. | 88.9% (8) | 11.1% (1) | 0 (0) | Q24. Ascertainment of adverse effects of medications prescribed to reduce breast cancer risk (please discuss which are most important and how you recommend they be studied). | 41.7% (5) | 25.0% (3) | 33.3% (4)
Q25. Evaluation of how long the beneficial effects of therapy last. | 100% (9) | 0 (0) | 0 (0) | Q25. Evaluation of the persistent effect of breast cancer risk reduction treatment. | 66.7% (8) | 25.0% (3) | 8.3% (1)
Additional Items | | | | Additional Items
Q27. Studies of doctors' attitudes toward prescribing medications to reduce breast cancer risk. | 33.3% (3) | 33.3% (3) | 33.3% (3) | Q27. Studies of clinicians' attitudes toward prescribing medications to reduce breast cancer risk. | 58.3% (7) | 16.7% (2) | 25.0% (3)
Q28. Studies of how doctors are weighing the risks and benefits of medications to reduce breast cancer risk. | 44.4% (4) | 33.3% (3) | 22.2% (2) | Q28. Studies of how clinicians are weighing the risks and benefits of prescribing medications to reduce breast cancer risk. | 75.0% (9) | 16.7% (2) | 8.3% (1)
Q29. Studies of doctors' attitudes toward recommending non-medication-related interventions to reduce breast cancer risk. | 22.2% (2) | 33.3% (3) | 44.4% (4) | Q29. Studies of clinicians' attitudes towards prescribing non-medication-related interventions to reduce breast cancer risk. | 33.3% (4) | 25.0% (3) | 41.7% (5)
Q30. Studies of patients’ attitudes toward taking medications to reduce breast cancer risk. | 44.4% (4) | 44.4% (4) | 11.1% (1) | Q30. Studies of patients' attitudes toward prescribing medications to reduce breast cancer risk. | 66.7% (8) | 16.7% (2) | 16.7% (2)
Q31. Studies of what factors influence a woman s decision-making about medications to reduce breast cancer risk. | 55.6% (5) | 44.4% (4) | 0 (0) | (Question not asked of Clinician/Research funder/Researcher)
Q32. Studies of how to communicate benefits and risk to patients. | 77.8% (7) | 22.2% (2) | 0 (0) | Q31. Studies of how to communicate benefits and risks to patients. | 83.3% (10) | 8.3% (1) | 8.3% (1)
Q33. Studies of how doctors and patients are working together to decide if medications to reduce risk of breast cancer should be prescribed. | 22.2% (2) | 66.7% (6) | 11.1% (1) | Q32. Studies of how clinicians and patients are working together to decide if medications to reduce risk of breast cancer should be prescribed. | 33.3% (4) | 41.7% (5) | 25.0% (3)
Q34. Research on predicting risk of breast cancer. | 88.9% (8) | 11.1% (1) | 0 (0) | Q33. Research on risk prediction models (please specify and recommend areas of improvement). | 75.0% (9) | 25.0% (3) | 0 (0)
Q35. If a current breast cancer risk prediction model were available, do you think patients would use it to help make decisions about therapy? Why or why not? | Yes; 100% (7) | No; 0 (0) | | Q34. If a current breast cancer risk prediction model were available, would you routinely use it in your practice? | Yes 100% (11) | No; 0 (0)

Looking across all structured questions, at least 50 percent of respondents in both Questionnaire I and II groups (consumer/policymaker and researcher/research funder/clinician, respectively) rated the following five questions as highest priority by PICO:

Population: | Studies of how age affects the benefits and/or harms of interventions to reduce the risk of breast cancer (78%; 75%)
Intervention: | Prescription medications: tamoxifen, raloxifene (50%; 55%)
Outcomes: | Evaluation of how long the beneficial effects of therapy last (100%; 67%)
Other: | Studies of how to communicate benefits and risk to patients (78%; 83%) and Research on predicting risk of breast cancer (89%; 75%)

Additionally, 100 percent of consumers, policymakers, clinicians, research funders, and researchers reported that patients would use a prediction model to assist in their decisionmaking if a current model were available. Compared with researchers, consumer advocates and policymakers were more interested in future research relating to the harms of therapy (89% vs. 42%). Narratives provided interesting differences in the criteria used for prioritization. Narratives from researchers indicated that harms of medications were either already known or that it was assumed they would be measured, as illustrated by this researcher who rated measurement of harms as low priority: “Already well documented. What is important is being able to predict who is most likely to have an adverse event and what can be done to prevent it.” This is in contrast to the comment from a policymaker that emphasizes the importance of looking for unintended consequences of recommendations: “Hate to possibly prescribe a drug to prevent breast cancer and she dies of a stroke or pulmonary embolism.”

Looking at narratives regarding the long-term beneficial effects of therapy, there was general agreement among all stakeholders that this was a priority though the rationale differed slightly. Consumers and policymakers commented that knowing the long-term beneficial effects of therapy would help them balance benefits and harmful effects and would motivate decisions to consider preventive therapy (implying prioritization of decisionmaking – influencing factor). On the other hand, researchers, funders, and clinicians commented that current studies have relatively short-term followup, and that long-term benefits such as survival are important to optimize duration of therapy (emphasizing outcome and intervention). Table 5 summarizes the top 10 priority research areas by rank order grouped according to questionnaire type.

Table 5 Top 10 priority research areas

Questionnaire I: Consumer/Policymaker^a^ | % High Priority a | Rank | Questionnaire II: Clinician/Research Funder/Researcher | % High Priority a | Rank
Persistent effect of preventive therapy | 100% | 1 | How to communicate benefits and risks to patients | 83.3% | 1
Reporting harmful effects of preventive therapy | 88.9% | 2 | Predicting risk of breast cancer | 75.0% | 2
Predicting risk of breast cancer | 88.9% | 2 | Understanding which populations of women would optimally benefit from medications to reduce the risk of breast cancer | 75.0% | 2
Studies of how to communicate benefits and risks to patients | 77.8% | 4 | How clinicians are weighing the risks and benefits to preventive therapy | 75.0% | 2
Studies of what populations optimally benefit from medications to reduce the risk of breast cancer | 77.8% | 4 | Persistent effect of preventive therapy | 66.7% | 5
Complementary and alternative therapies | 66.7% | 6 | Patient attitudes toward prescribing medications to reduce breast cancer risk | 66.7% | 5
Studies of how race and/or ethnicity affect interventions to reduce the risk of breast cancer | 66.7% | 6 | Studies of clinicians’ attitudes towards prescribing medications | 58.3% | 7
Molecular targeted drugs specific to cancer pathways | 62.5% | 8 | Aromatase Inhibitors | 54.5% | 8
What factors influence a woman’s decision-making to take medications to reduce breast cancer risk | 55.6% | 9 | SERMs | 54.5% | 8
SERMs | 50.0% | 10 | Gene-based drugs | 54.5% | 8
Combination therapies: i.e., prescription medications + diet | 50.0% | 10

Abbreviations: SERM= selective estrogen receptor modulator.

a Percentages indicate a priority ranking of “high” by respondents from choices of “high,” “medium,” or “low.”

According to the ranking of responses to the structured list, consumers and policymakers more frequently rated studies of interventions as high priority, followed by population, influencing factors, and outcomes, whereas researchers, research funders, and clinicians more frequently rated other factors highest, followed by intervention studies, and then outcomes.

### Preferences for Future Research Dissemination

Lastly, we asked stakeholders to indicate how they would like to receive results from this national research stakeholder prioritization process (Table 6). Clinicians, researchers, and funders unanimously preferred to receive the document as a journal article whereas consumers and policymakers unanimously preferred a standalone document.

Table 6 Preferred format to receive future research documents

Questionnaire I: Consumer/Policymaker | | Questionnaire II: Clinician/Research Funder/Researcher
Format | Percent (n ) | Format | Percent (n)
Chapter in an evidence report | 25% (2) | Chapter in an evidence report | 8.3% (1)
Magazine article | 25% (2) | Journal article | 100% (12)
Stand alone document | 100% (8) | Standalone document | 33.3% (4)
Webinar | 25% (2) | Webinar | 25% (3)
Podcast | 0% | Podcast | 8.3% (1)
Other (please specify) Publication in a highly visible journal with links to online document | 12.5% (1) | Other (please specify) Summary email with links | 8.3% (1)