# References

1 Cancer Facts & Figures. 2010. Available at http://www.cancer.org/acs/groups/content/@nho/documents/document/acspc-024113.pdf.
2 Nelson H, Fu R, Griffin J, et al. Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer. Ann Intern Med. 2009;151(10):703-715. [pmid: 19920271].
3 Nelson H, Fu R, Humphrey L, et al. Comparative effectiveness of medications to reduce risk of primary breast cancer in women, Comparative effectiveness review No 17. Rockville, MD. Agency for Healthcare Research and Quality. 2009.
4 Brown P, Brunnhuber K, Chalkidou K, et al. How to formulate research recommendations. British Medical Journal. Oct 14. 2006;333(7572):804-806. [pmid: 17038740].
5 Dobscha S, Campbell R, Morasco B, et al. Pain in patients with polytrauma: A systematic review. 2008.
6 Guise J-M, Eden K, Emeis C, et al. Vaginal Birth After Cesarean: New Insights, Evidence Report/Technology Assessment No.191. (Prepared by the Oregon Health & Science University Evidence-based Practice Center under Contract No. 290-2007-10057-I). 2010.
7 Chalkidou K, Whicher D, Kary W, et al. Comparative effectiveness research priorities: identifying critical gaps in evidence for clinical and health policy decision making. Int J Technol Assess Health Care. 2009;25:241-248. [pmid: 19619341].
8 Gold R. Personal communication. December. 19. 2009.
9 RTI/UNC. 2006 RTI Collaboration Fund Proposal: Collaborative Meeting on Mode of Delivery. 2006.
10 Corbin J, Strauss A. Basics of qualitative research. 3rd Edition. Thousand Oaks, CA. Sage Publications. 2008.
11 Whitlock E, Orleans C, Pender N, et al. Evaluating primary care behavioral counseling interventions: An evidence-based approach. Am J Prev Med. 2002;22(4):267-284. [pmid: 11988383].
12 Guise J-M, Denman M, Emeis C, et al. Vaginal birth after cesarean: new insights on maternal and neonatal outcomes. Obstet Gynecol. Jun. 2010;115(6):112-113.
13 Nelson H. Statistical Coordinating Center for the Breast Cancer Screening Surveillance Consortium. August. 4. 2010.
14 Kaplan CP, Haas JS, Perez-Stable EJ, et al. Factors affecting breast cancer risk reduction practices among California physicians. Preventive Medicine. Jul. 2005;41(1):7-15. [pmid: 15916987].
15 NCT00001898. Microarray Analysis for Human Genetic Disease. 2008.
16 Reding KW, Weiss NS, Chen C, et al. Genetic polymorphisms in the catechol estrogen metabolism pathway and breast cancer risk. Cancer Epidemiology, Biomarkers & Prevention. May. 2009;18(5):1461-1467.
17 Risk M-GCoGSfMHTRBC. Genetic polymorphisms in phase I and phase II enzymes and breast cancer risk associated with menopausal hormone therapy in postmenopausal women [Erratum appears in Breast Cancer Res Treat 2010 Jan;119(2):475]. Breast Cancer Research & Treatment. Jan. 2010;119(2):463-474. [pmid: 19424794].
18 Sinilnikova OM, Antoniou AC, Simard J, et al. The TP53 Arg72Pro and MDM2 309G>T polymorphisms are not associated with breast cancer risk in BRCA1 and BRCA2 mutation carriers. British Journal of Cancer. Oct 20. 2009;101(8):1456-1460. [pmid: 19707196].
19 Konwisorz A, Springwald A, Haselberger M, et al. Knockdown of ICB-1 gene enhanced estrogen responsiveness of ovarian and breast cancer cells. Endocrine-Related Cancer. Mar. 2010;17(1):147-157. [pmid: 19942713].
20 Kuderer NM, Peppercorn J. CYP2D6 testing in breast cancer: ready for prime time?. Oncology. Dec. 2009;23(14):1223-1232. [pmid: 20120834].
21 Zhang Y, Su H, Rahimi M, et al. EGFRvIII-induced estrogen-independence, tamoxifen-resistance phenotype correlates with PgR expression and modulation of apoptotic molecules in breast cancer. International Journal of Cancer. Nov 1. 2009;125(9):2021-2028. [pmid: 19588487].
22 Zhuo W, Zhang Y, Xiang Z, et al. Polymorphisms of TP53 codon 72 with breast carcinoma risk: evidence from 12226 cases and 10782 controls. Journal of Experimental & Clinical Cancer Research. 2009;28:115. [pmid: 19682377].
23 Ye C, Shu XO, Pierce L, et al. Mutations in the mitochondrial DNA D-loop region and breast cancer risk. Breast Cancer Research & Treatment. Jan. 2010;119(2):431-436. [pmid: 19381801].
24 Breyer JP, Sanders ME, Airey DC, et al. Heritable variation of ERBB2 and breast cancer risk. Cancer Epidemiology, Biomarkers & Prevention. Apr. 2009;18(4):1252-1258.
25 Chakraborty A, Mishra AK, Soni A, et al. Vitamin D receptor gene polymorphism(s) and breast cancer risk in north Indians. Cancer Detection & Prevention. 2009;32(5–6):386-394. [pmid: 19588543].
26 Cleveland RJ, Gammon MD, Long C-M, et al. Common genetic variations in the LEP and LEPR genes, obesity and breast cancer incidence and survival. Breast Cancer Research & Treatment. Apr. 2010;120(3):745-752. [pmid: 19697123].
27 Iwasaki M, Hamada GS, Nishimoto IN, et al. Isoflavone, polymorphisms in estrogen receptor genes and breast cancer risk in case-control studies in Japanese, Japanese Brazilians and non-Japanese Brazilians. Cancer Science. May. 2009;100(5):927-933. [pmid: 19298602].
28 Higgins MJ, Rae JM, Flockhart DA, et al. Pharmacogenetics of tamoxifen: who should undergo CYP2D6 genetic testing?. Journal of the National Comprehensive Cancer Network. Feb. 2009;7(2):203-213. [pmid: 19200418].
29 Gould MN. The utility of comparative genetics to inform breast cancer prevention strategies. Genetics. Oct. 2009;183(2):409-412. [pmid: 19864342].
30 Gail MH. Value of adding single-nucleotide polymorphism genotypes to a breast cancer risk model. Journal of the National Cancer Institute. Jul 1. 2009;101(13):959-963. [pmid: 19535781].
31 Economopoulos KP, Sergentanis TN. Differential effects of MDM2 SNP309 polymorphism on breast cancer risk along with race: a meta-analysis. Breast Cancer Research & Treatment. Feb. 2010;120(1):211-216. [pmid: 19590949].
32 NCT00291096. Protocol for Women at Increased Risk of Developing Breast Cancer.
33 5R01CA132879-02. Risk Prediction for Breast Cancer: A Tissue-based Strategy. 2008.
34 Ready K, Litton JK, Arun BK. Clinical application of breast cancer risk assessment models. Future Oncology. Mar. 2010;6(3):355-365. [pmid: 20222793].
35 Rowan K. Beyond the Gail model: lobular involution may help refine breast cancer risk assessment. Journal of the National Cancer Institute. Feb 4. 2009;101(3):134-135. [pmid: 19176450].
36 Schonfeld SJ, Pee D, Greenlee RT, et al. Effect of changing breast cancer incidence rates on the calibration of the Gail model. Journal of Clinical Oncology. May 10. 2010;28(14):2411-2417. [pmid: 20368565].
37 Stone J, Warren RML, Pinney E, et al. Determinants of percentage and area measures of mammographic density. American Journal of Epidemiology. Dec 15. 2009;170(12):1571-1578. [pmid: 19910376].
38 Komata D, Yahata T, Kodama S, et al. The prevalence of hereditary breast/ovarian cancer risk in patients with a history of breast or ovarian cancer in Japanese subjects. Journal of Obstetrics & Gynaecology Research. Oct. 2009;35(5):912-917. [pmid: 20149041].
39 Amir E, Freedman OC, Seruga B, et al. Assessing women at high risk of breast cancer: a review of risk assessment models. Journal of the National Cancer Institute. May 19. 2010;102(10):680-691. [pmid: 20427433].
40 Berg WA. Tailored supplemental screening for breast cancer: what now and what next?. AJR. Feb. 2009;192(2):390-399. [pmid: 19155400].
41 Cummings SR, Tice JA, Bauer S, et al. Prevention of breast cancer in postmenopausal women: approaches to estimating and reducing risk. Journal of the National Cancer Institute. Mar 18. 2009;101(6):384-398. [pmid: 19276457].
42 Jacobi CE, de Bock GH, Siegerink B, et al. Differences and similarities in breast cancer risk assessment models in clinical practice: which model to choose?. Breast Cancer Research & Treatment. May. 2009;115(2):381-390. [pmid: 18516672].
43 Gjorgov NA. Breast cancer risk assessments to barrier contraception exposure. A new approach. Makedonska Akademija na Naukite i Umetnostite Oddelenie Za Bioloshki i Meditsinski Nauki Prilozi. Jul. 2009;30(1):217-232.
44 NCT00976339. Study of Vitamin D for Premenopausal Women at High Risk for Breast Cancer.
45 NCT00917735. Green Tea and Reduction of Breast Cancer Risk. 2013.
46 NCT00256217. Chemoprevention Trial—Anastrozole in Ductal Carcinoma In Situ (DCIS) in Postmenopausal Women. 2012.
47 NCT00579826. Study of Breast Cancer Prevention by Letrozole in High Risk Women. 2011.
48 NCT00762294. Anastrozole and Letrozole.
49 NCT00165308. Tamoxifen in the Prevention of Breast Cancer in Hodgkin’s Disease Survivors. 2010.
50 NCT00914017. Statins and Breast Cancer Biomarkers.
51 NCT00285857. Phase II Trial—Breast Cancer Chemoprevention by Lovastatin.
52 NCT00080756. Deslorelin Combined With Low-Dose Add-Back Estradiol and Testosterone in Preventing Breast Cancer in Premenopausal Women Who Are at High Risk for This Disease.
53 NCT01060345. A Pilot Study of Chemo-prevention of Green Tea in Women With Ductal Carcinoma in Situ. 2012.
54 NCT01097278. High Dose Cholecalciferol in Premenopausal Women at High-Risk for Breast Cancer.
55 NCT01127867. A Pilot Study of Docosahexaenoic Acid (DHA) in Obese Menopausal Women. 2012.
56 NCT00611104. Studying the Effect of Freeze-Dried Table Grape Powder on Blood Estrogen Levels in Postmenopausal Women.
57 NCT00290758. Phase IIb Trial of G-2535 (Unconjugated Isoflavones-100) in Women at High Risk for Breast Cancer. 2011.
58 NCT00470119. Effect of a Low-Calorie Diet and/or Exercise Program on Risk Factors for Developing Breast Cancer in Overweight or Obese Postmenopausal Women.
59 NCT00712647. Carotene and Retinol Efficacy Trial. 2018.
60 NCT00291135. Protocol for Women at Increased Risk of Developing Breast Cancer. 2009.
61 NCT00393172. Exercise in Preventing Breast Cancer in Healthy Young Women.
62 NCT00522262. Alberta Physical Activity and Breast Cancer Prevention (ALPHA) Trial. 2007.
63 NCT00723398. Nutritional Supplements and Hormonal Manipulations for Breast Cancer Prevention. 2012.
64 NCT00967239. Study of Blood Samples From High-Risk Postmenopausal Women Who Received Treatment on Breast Cancer Prevention Clinical Trials NSABP-P-1 or NSABP-P-2.
65 NCT00073073. Exemestane and Celecoxib in Postmenopausal Women at High Risk for Breast Cancer. 2010.
66 NCT00588029. Collection of Tissue, Blood, and Cells to Be Used For Studying the Causes, Prevention, Diagnosis, and Treatment of Breast Cancer. 2010.
67 NCT00899938. Collecting Samples of Normal Breast Tissue, Primary Breast Cancer Tissue, and Metastatic Breast Cancer Tissue for Genetic Analysis in Women With or Without Breast Cancer.
68 5R03CA141485-02. Oral Contraceptive Use by Formulation and Breast Cancer Risk by Subtype. 2009.
69 1R01CA138580-01A2. Growth hormones and breast cancer risk. 2010.
70 5R03CA128010-02. A Population Based Study of Birth Characteristics and Maternal Breast Cancer. 2007.
71 5R01CA081243-09. Carcinogenicity of Estrogens. 2000.
72 1RC2CA148507-01. The Molecular Basis of Pregnancy-Associated Protection from Breast Cancer. 2009.
73 2P01CA033619-21A1. Molecular Epidemiology of Nutrition and Cancer in the Multiethnic Cohort Study. 1983.
74 5R01CA116623-06. Fatty Acid Synthase Molecular Target for Breast Cancer Therapy & Chemoprevention. 2005.
75 5U01CA049449-21. Biochemical Markers in the Nurses, Health Study Cohort. 1989.
76 NCT00291083. Protocol for Postmenopausal Women at Increased Risk of Developing Breast Cancer. 2008.
77 Kato I, Cichon M, Yee CL, et al. African American-preponderant single nucleotide polymorphisms (SNPs) and risk of breast cancer. Cancer Epidemiology. Jul. 2009;33(1):24-30. [pmid: 19679043].
78 Kerlikowske K, Molinaro AM, Gauthier ML, et al. Biomarker expression and risk of subsequent tumors after initial ductal carcinoma in situ diagnosis. Journal of the National Cancer Institute. May 5. 2010;102(9):627-637. [pmid: 20427430].
79 Li H, Ha TC, Tai BC. XRCC1 gene polymorphisms and breast cancer risk in different populations: a meta-analysis. Breast. Jun. 2009;18(3):183-191. [pmid: 19446452].
80 Nasir A, Shackelford RE, Anwar F, et al. Genetic risk of breast cancer. Minerva Endocrinologica. Dec. 2009;34(4):295-309. [pmid: 20046159].
81 Olson JE, Wang X, Goode EL, et al. Variation in genes required for normal mitosis and risk of breast cancer. Breast Cancer Research & Treatment. Jan. 2010;119(2):423-430. [pmid: 19377877].
82 Pieta B, Samulak D, Opala T, et al. Analysis of odds ratio of increased relative risk of developing breast cancer in different groups of women. European Journal of Gynaecological Oncology. 2010;31(1):50-54. [pmid: 20349781].
83 Lambe M, Johansson ALV, Altman D, Eloranta S. Mastitis and the risk of breast cancer. Epidemiology. Sep. 2009;20(5):747-751. [pmid: 19688877].
84 Oberg S, Cnattingius S, Sandin S, et al. Birth weight-breast cancer revisited: is the association confounded by familial factors?. Cancer Epidemiology, Biomarkers & Prevention. Sep. 2009;18(9):2447-2452.
85 Welsh ML, Buist DSM, et al. Population-based estimates of the relation between breast cancer risk, tumor subtype, and family history. Breast Cancer Research & Treatment. Apr. 2009;114(3):549-558. [pmid: 18437558].
86 Bjorge T, Cnattingius S, Engeland A, et al. Fetal Down syndrome and the risk of maternal breast cancer. Epidemiology. Jul. 2009;20(4):584-589. [pmid: 19451822].
87 Calderon-Margalit R, Friedlander Y, Yanetz R, et al. Cancer risk after exposure to treatments for ovulation induction. American Journal of Epidemiology. Feb 1. 2009;169(3):365-375. [pmid: 19037008].
88 Cazzaniga M, Decensi A, Bonanni B, et al. Biomarkers for risk assessment and prevention of breast cancer. Current Cancer Drug Targets. Jun. 2009;9(4):482-499. [pmid: 19519317].
89 Gunter MJ, Hoover DR, Yu H, et al. Insulin, insulin-like growth factor-I, and risk of breast cancer in postmenopausal women. Journal of the National Cancer Institute. Jan 7. 2009;101(1):48-60. [pmid: 19116382].
90 Gutierrez RL, Demartini WB, Eby P, et al. Clinical indication and patient age predict likelihood of malignancy in suspicious breast MRI lesions. Academic Radiology. Oct. 2009;16(10):1281-1285. [pmid: 19733804].
91 Gaudet MM, Milne RL, Cox A, et al. Five polymorphisms and breast cancer risk: results from the Breast Cancer Association Consortium. Cancer Epidemiology, Biomarkers & Prevention. May. 2009;18(5):1610-1616.
92 Gajalakshmi V, Mathew A, Brennan P, et al. Breastfeeding and breast cancer risk in India: a multicenter case-control study. International Journal of Cancer. Aug 1. 2009;125(3):662-665. [pmid: 19452516].
93 Epplein M, Novotny R, Daida Y, et al. Association of maternal and intrauterine characteristics with age at menarche in a multiethnic population in Hawaii. Cancer Causes & Control. Feb. 2010;21(2):259-268. [pmid: 19862633].
94 de Haan MC, Michels KB, Peeters PHM, et al. Age of mother and grandmother in relation to a subject’s breast cancer risk. British Journal of Cancer. Apr 27. 2010;102(9):1400-1404. [pmid: 20354520].
95 Dey S, Boffetta P, Mathews A, et al. Risk factors according to estrogen receptor status of breast cancer patients in Trivandrum, South India. International Journal of Cancer. Oct 1. 2009;125(7):1663-1670. [pmid: 19452528].
96 Awatef M, Olfa G, Imed H, et al. Breastfeeding reduces breast cancer risk: a case-control study in Tunisia. Cancer Causes & Control. Mar. 2010;21(3):393-397. [pmid: 19921444].
97 NCT00849199. Cancer Screening and Prevention Program for High Risk Women. 2013.
98 NCT01034891. Women At Risk: The High Risk Breast Cancer Program.
99 NCT00555503. Registry of Mastectomy for Breast Cancer Risk Reduction. 2012.
100 Cancer Prevention Study II. American Cancer Society.
101 3R01CA092447-08S1. Southern Community Cohort Study. 2001.
102 5R37CA070867-13. Cancer Risk Reduction and Diet: A Cohort Study of Women. 1996.
103 Cancer Prevention Study. 3. American Cancer Society.
104 Palmer JR, Boggs DA, Adams-Campbell LL, et al. Family history of cancer and risk of breast cancer in the Black Women's Health Study. Cancer Causes & Control. Nov. 2009;20(9):1733-1737. [pmid: 19760028].
105 NCT00873366. Breath Test for Women Receiving Tamoxifen in the Prevention or Treatment of Breast Cancer.
106 ACTRN12605000282684. International Breast cancer Intervention Study II (IBIS-II) DCIS Protocol, An international multicentre study of tamoxifen vs anastrozole in postmenopausal women with hormone sensitive Ductal Carcinoma In Situ (DCIS).
107 1U01CA141550-01. Preventive Interventions Leadership U01. 2009.
108 5R01CA114068-04. Molecular Markers of Breast Cancer Risk and Prevention. 2006.
109 NCT00083044. Ductal Lavage in Assessing Women With Early Breast Cancer or at High Risk of Developing Breast Cancer and Who Are Eligible For Tamoxifen Therapy.
110 NCT00228930. Tamoxifen Pharmacogenetics and Clinical Effects. 2007.
111 5R03CA136071-02. Evaluation of 3D MRI-based Quantitative Breast Density for Chemoprevention. 2009.
112 NCT00830973. The Clinical and Economic Impact of Pharmacogenomic Testing for Tamoxifen Metabolism in Postmenopausal Women Receiving Tamoxifen for Prevention of Recurrent Breast Cancer. 2009.
113 Layeequr Rahman R, Crawford S. Chemoprevention Indication Score: a user-friendly tool for prevention of breast cancer-pilot analysis. Breast. Oct. 2009;18(5):289-293. [pmid: 19716702].
114 NCT00797199. Monitoring of Breast Tissue Change Due to Hormone Replacement Therapy in Post-menopausal Women Using OBS. 2010.
115 NCT00340600. Continuation of Follow-up of DES-Exposed Cohorts.
116 Garber JE. Preclinical and brief exposure early clinical evaluation of an oral PARP inhibitor for breast cancer prevention in BRCA mutation carriers. Komen Research Grants 2009—2010 Grant Cycle.
117 NCT00342407. The Incidence of Breast and Other Cancers Among Female Flight Attendants.
118 Keen JD, Keen JE. What is the point: will screening mammography save my life?. BMC Medical Informatics & Decision Making. 2009;9:18. [pmid: 19341448].
119 Khoury-Shakour S, Lejbkowicz F, Barnett-Griness O, et al. Genetic variation in IGF-1 and breast cancer risk in Ashkenazi carriers and noncarriers of BRCA1/2 mutations. European Journal of Cancer Prevention. Sep. 2009;18(5):361-367. [pmid: 19543094].
120 Metcalfe KA, Finch A, Poll A, et al. Breast cancer risks in women with a family history of breast or ovarian cancer who have tested negative for a BRCA1 or BRCA2 mutation. British Journal of Cancer. Jan 27. 2009;100(2):421-425. [pmid: 19088722].
121 Onitilo AA, McCarty CA, Wilke RA, et al. Estrogen receptor genotype is associated with risk of venous thromboembolism during tamoxifen therapy. Breast Cancer Research & Treatment. Jun. 2009;115(3):643-650. [pmid: 19082882].
122 Li Y, Brown PH. Prevention of ER-negative breast cancer. Recent Results in Cancer Research. 2009;181:121-134. [pmid: 19213564].
123 Baumann CK, Castiglione-Gertsch M. Clinical use of selective estrogen receptor modulators and down regulators with the main focus on breast cancer. Minerva Ginecologica. Dec. 2009;61(6):517-539. [pmid: 19942839].
124 Brauch H, Jordan VC. Targeting of tamoxifen to enhance antitumour action for the treatment and prevention of breast cancer: the ‘personalised’ approach?. European Journal of Cancer. Sep. 2009;45(13):2274-2283. [pmid: 19592233].
125 Cybulski C, Huzarski T, Byrski T, et al. Estrogen receptor status in CHEK2-positive breast cancers: implications for chemoprevention. Clinical Genetics. Jan. 2009;75(1):72-78. [pmid: 19021634].
126 3R01CA112176-05S1. Progression and regression of mammary preneoplasia. 2004.
127 5577 PC-S-PI. Carcinogenesis Program.
128 1ZIASC006663-20. Molecular characterization of breast duct epithelium at risk for breast cancer.
129 5R01CA105204-05. Exercise, Diet, and Sex Hormones in Postmenopausal Women. 2004.
130 1RC1ES018411-01. Validated Biomarkers for Primary Macronutrient Balance. 2009.
131 NCT00639210. Breast Cancer and Exercise. 2007.
132 NCT00572351. The Effects of Red Wine and White Wine on Blood Estrogen and Progesterone Levels. 2007.
133 NCT00359060. Physical Activity and Breast Cancer Risk in Postmenopausal Women the SHAPE Study. 2006.
134 NCT00120016. Design and Feasibility of a Mediterranean Diet. 2007.
135 NCT00148057. Diet and Breast Cancer Prevention Trial. 2005.
136 NCT00000611. Women’s Health Initiative (WHI).
137 5R01CA100693-06. Exercise, Breast Cancer Prevention, and Mechanisms. 2003.
138 5U01ES016048-04. Macronutrients, Mitochondria and Blood Metabolome/Proteome Disease Risk Profiles. 2007.
139 Ma E, Iwasaki M, Junko I, et al. Dietary intake of folate, vitamin B6, and vitamin B12, genetic polymorphism of related enzymes, and risk of breast cancer: a case-control study in Brazilian women. BMC Cancer. 2009;9:122. [pmid: 19389261].
140 Maruti SS, Ulrich CM, White E. Folate and one-carbon metabolism nutrients from supplements and diet in relation to breast cancer risk. American Journal of Clinical Nutrition. Feb. 2009;89(2):624-633. [pmid: 19116331].
141 Peters TM, Moore SC, Gierach GL, et al. Intensity and timing of physical activity in relation to postmenopausal breast cancer risk: the prospective NIH-AARP diet and health study. BMC Cancer. 2009;9:349. [pmid: 19796379].
142 Schmidt ME, Chang-Claude J, Slanger T, et al. Physical activity and postmenopausal breast cancer: effect modification by other breast cancer risk factors. Methods of Information in Medicine. 2009;48(5):444-450. [pmid: 19696953].
143 Stuebe AM, Willett WC, Xue F, et al. Lactation and incidence of premenopausal breast cancer: a longitudinal study. Archives of Internal Medicine. Aug 10. 2009;169(15):1364-1371. [pmid: 19667298].
144 Tworek C, Nadpara P, Adkins B, et al. Smoking and breast cancer screening in West Virginia: opportunities for intervention. West Virginia Medical Journal. Oct. 2009;105(Spec No):48-53. [pmid: 19999266].
145 Wen W, Shu XO, Li H, et al. Dietary carbohydrates, fiber, and breast cancer risk in Chinese women. American Journal of Clinical Nutrition. Jan. 2009;89(1):283-289. [pmid: 19056583].
146 Butler LM, Gold EB, Conroy SM, et al. Active, but not passive cigarette smoking was inversely associated with mammographic density. Cancer Causes & Control. Feb. 2010;21(2):301-311. [pmid: 19915951].
147 Cottet V, Touvier M, Fournier A, et al. Postmenopausal breast cancer risk and dietary patterns in the E3N-EPIC prospective cohort study. American Journal of Epidemiology. Nov 15. 2009;170(10):1257-1267. [pmid: 19828509].
148 Jayalekshmi P, Varughese SC, Kalavathi, et al. A nested case-control study of female breast cancer in Karunagappally cohort in Kerala, India. Asian Pacific Journal of Cancer Prevention. Apr–Jun. 2009;10(2):241-246. [pmid: 19548367].
149 NCT00118846. Women’s Isoflavone Soy Health (WISH) Trial. 2009.
150 NCT01022333. The Potential for Oral Diindolylmethane (DIM) Supplementation to Increase the Production of the BRCA1 Protein in BRCA1 Mutation Carriers. 2010.
151 NCT00794989. Flaxseed in Preventing Breast Cancer in Premenopausal Women at Risk of Developing Breast Cancer.
152 NCT00859651. Vitamin D in Postmenopausal Women at High Risk for Breast Cancer.
153 NCT01089049. Effect of a Natural Health Product on Urinary Estrogen Metabolites. 2010.
154 NCT00982319. Study to Evaluate the Effect of Sulforaphane in Broccoli Sprout Extract on Breast Tissue. 2010.
155 NCT01052051. Clinical Trial of Vitamin D3 to Reduce Cancer Risk in Postmenopausal Women. 2014.
156 NCT00566553. The Effect of Grape Seed Extract on Estrogen Levels of Postmenopausal Women. 2010.
157 NCT00204490. Soy Isoflavones and Breast Cancer Risk Reduction. 2012.
158 NCT00204477. Soy Protein and Breast Cancer Risk Reduction. 2012.
159 NCT00100893. IH636 Grape Seed Extract in Preventing Breast Cancer in Postmenopausal Women at Risk of Developing Breast Cancer.
160 ACTRN12609000098235. A pilot randomised controlled trial to evaluate the effects of Green Tea Polyphenols on Serum Hormone Levels in healthy women.
161 NCT00262184. A Taiwan Isoflavone Multicenter Study (TIMS). 2007.
162 Fabian C. The lignan SDG as a prevention strategy for pre-menopausal women at high risk for development of breast cancer. Komen Research Grants 2009—2010 Grant Cycle.
163 NCT00114296. Omega-3 Fatty Acids in Preventing Breast Cancer in Women at High Risk of Developing Breast Cancer.
164 NCT00555386. Soy, Selenium and Breast Cancer Risk. 2008.
165 NCT00200824. Effects of Soy Compounds on Breast Cancer, Prostate Cancer, and Bone Health. 2005.
166 NCT00099008. Genistein in Preventing Breast or Endometrial Cancer in Healthy Postmenopausal Women.
167 5R01CA114018-03. Omega-3 Fatty Acids to Reduce Risk for Breast Cancer. 2007.
168 3U54CA100949-05S1. Center for Nutrient-Gene Interaction in Cancer Prevention. 2003.
169 5413 GR-S-PI. ACT 2 PROJ 3 Studies on the Anti-Breast Cancer Function of Bamboo Extract. 2009.
170 1ZIADK056009-03. Chemoprevention and therapeutic treatment of BRCA1 associated with mammary tumors.
171 5R03CA136014-02. A Synthetic Triterpenoid in Breast Cancer Chemoprevention. 2009.
172 5K01AT001692-03. Anticancer Potential of Black Cohosh on Breast Cancer. 2005.
173 5R01CA129347-03. Breast Cancer Prevention by Dietary Phytochemicals. 2007.
174 5R01CA127614-03. Epigenetics of the Retinoic Acid Paradox. 2008.
175 5R01CA121211-04. Dietary Chemopreventive Components/Oncogene Interaction and Cancer. 2007.
176 5R01CA125152-04. Breast Cancer Chemoprevention Potential of Common Spices. 2007.
177 5R21CA135478-02. Reactivation of Tumor Suppressor Genes in Breast Cancer by Dietary Supplements As. 2009.
178 5F32AT004876-02. Chemopreventative Properties of Medicinal and Food Plants of the Lumbee Tribe. 2008.
179 0007 PC-S-PI. UAB Rexinoids for Breast Cancer Prevention.
180 Christov K. Role of a novel RAR-beta-5 isoform in the resistance of breast cancer cells to retinoids. Komen Research Grants 2009—2010 Grant Cycle.
181 NCT00020098. Complementary or Alternative Medicine Practices Used by Women at Increased Risk for Breast Cancer.
182 NCT00513916. Effect of Dietary Soy on Estrogens in Breast Fluid, Blood, and Urine Samples From Healthy Women.
183 1ZIACP010169-08. Nutrition, Metabolism, and Cancer.
184 Ogunleye AA, Xue F, Michels KB. Green tea consumption and breast cancer risk or recurrence: a meta-analysis. Breast Cancer Research & Treatment. Jan. 2010;119(2):477-484. [pmid: 19437116].
185 Puntoni M, Decensi A. The rationale and potential of cancer chemoprevention with special emphasis on breast cancer. European Journal of Cancer. Sep. 2009;45(Suppl 1):346-354. [pmid: 19775631].
186 NCT01077453. Letrozole in Treating Healthy Postmenopausal Women at High Risk for Breast Cancer.
187 NCT00083174. Exemestane in Preventing Cancer in Postmenopausal Women at Increased Risk of Developing Breast Cancer. 2011.
188 ACTRN12605000216617. International Breast cancer Intervention Study II (IBIS-II) Prevention Protocol, An international multicentre study of anastrozole vs placebo in postmenopausal women at increased risk of breast cancer.
189 NCT00078832. Anastrozole in Preventing Breast Cancer in Postmenopausal Women at Increased Risk of Breast Cancer.
190 NCT00280930. Letrozole in Postmenopausal Women at Increased Risk for Breast Cancer.
191 NCT00066586. Exemestane in Reducing Breast Density in Postmenopausal Women at Risk for Breast Cancer. 2009.
192 NCT00200174. Combined Estrogen Blockade of the Breast With Exemestane and Raloxifene in Postmenopausal Women With a History of Breast Cancer Who Have No Clinical Evidence of Disease. 2008.
193 NCT00238316. Letrozole in Preventing Breast Cancer in Postmenopausal Women Who Are at Increased Risk for Breast Cancer Due to High Breast Density. 2009.
194 Al-Fozan HM, Al-Inany HG, Bedaiwy MA, et al. Aromatase inhibitors for ovulation induction. Cochrane Database of Systematic Reviews. 2009;(1).
195 Dunn BK, Ryan A. Phase 3 trials of aromatase inhibitors for breast cancer prevention: following in the path of the selective estrogen receptor modulators. Annals of the New York Academy of Sciences. Feb. 2009;1155:141-161. [pmid: 19250201].
196 ACTRN12610000134022. An international multi-centre study of tamoxifen vs placebo in women at increased risk of breast cancer.
197 NCT00003906. Study of Tamoxifen and Raloxifene (STAR) for the Prevention of Breast Cancer in Postmenopausal Women. 2014.
198 NCT00096369. Tamoxifen in Preventing Breast Cancer in Women at Increased Risk for Breast Cancer.
199 ISRCTN91879928. An international multicentre study of tamoxifen versus placebo in women at increased risk of breast cancer.
200 NCT00853996. Acolbifene for Breast Cancer Chemoprevention. 2011.
201 NCT00005879. LY353381 in Preventing Breast Cancer in Women With Hyperplasia.
202 NCT00295100. Tamoxifen-MRI Study. 2006.
203 NCT00253539. Arzoxifene or Tamoxifen in Preventing Breast Cancer in Premenopausal Women at High Risk for Breast Cancer.
204 ISRCTN07027313. Randomised double blind trial to evaluate prevention of breast cancer using tamoxifen in high risk women.
205 NCT00190593. Raloxifene Use for The Heart. 2005.
206 NCT00086749. Effect of Tamoxifen on Breast Density in Premenopausal Women With Breast Cancer or High Risk for Breast Cancer.
207 NCT00019500. Raloxifene in Preventing Breast Cancer in Premenopausal Women.
208 Wickerham DL, Costantino JP, Vogel VG, et al. The use of tamoxifen and raloxifene for the prevention of breast cancer. Recent Results in Cancer Research. 2009;181:113-119. [pmid: 19213563].
209 Cummings SR, Ensrud K, Delmas PD, et al. Lasofoxifene in postmenopausal women with osteoporosis. New England Journal of Medicine. Feb 25. 2010;362(8):686-696. [pmid: 20181970].
210 Decensi A, Robertson C, Guerrieri-Gonzaga A, et al. Randomized double-blind 2 x 2 trial of low-dose tamoxifen and fenretinide for breast cancer prevention in high-risk premenopausal women. Journal of Clinical Oncology. Aug 10. 2009;27(23):3749-3756. [pmid: 19597031].
211 5R01CA133049-03. Tamoxifen Biotransformation Pathway Pharmacogenomics. 2008.
212 5R01CA079870-11. Carcinogenic Metabolites Formed From Antiestrogen. 1999.
213 Hursting SD. The Breast Cancer Research & Treatment 2009—2010.
214 Ponce-Balbuena D, Lopez-Izquierdo A, Ferrer T, et al. Tamoxifen inhibits inward rectifier K+ 2.x family of inward rectifier channels by interfering with phosphatidylinositol 4,5-bisphosphate-channel interactions. Journal of Pharmacology & Experimental Therapeutics. Nov. 2009;331(2):563-573. [pmid: 19654266].
215 Peng J, Sengupta S, Jordan VC. Potential of selective estrogen receptor modulators as treatments and preventives of breast cancer. Current Medicinal Chemistry—Anti-Cancer Agents. Jun. 2009;9(5):481-499.
216 da Silva BB, Pires CG, dos Santos AR, et al. Effects of raloxifene on Ki-67 and CD34 antigen expression in breast cancer. Gynecologic & Obstetric Investigation. 2009;67(2):103-108. [pmid: 18953168].
217 Dai H, Zhang P, Zhao S, et al. Regulation of the vascular endothelial growth factor and growth by estrogen and antiestrogens through Efp in Ishikawa endometrial carcinoma cells. Oncology Reports. Feb. 2009;21(2):395-401. [pmid: 19148513].
218 DuSell CD, Nelson ER, Wittmann BM, et al. Regulation of aryl hydrocarbon receptor function by selective estrogen receptor modulators. Molecular Endocrinology. Jan. 2010;24(1):33-46. [pmid: 19901195].
219 Clarke BL, Khosla S. New selective estrogen and androgen receptor modulators. Current Opinion in Rheumatology. Jul. 2009;21(4):374-379. [pmid: 19412100].
220 Cutuli B, Lesur A, Namer M, et al. Breast cancer chemoprevention. Rational, trials results and future. Bulletin du Cancer. May. 2009;96(5):519-530. [pmid: 19467983].
221 Inoue D. Effects of SERMs on bone health. Raloxifene effects on breast cancer and cardiovascular events. Clinical Calcium. Mar. 2010;20(3):331-338. [pmid: 20190362].
222 Hernandez RK, Sorensen HT, Pedersen L, et al. Tamoxifen treatment and risk of deep venous thrombosis and pulmonary embolism: a Danish population-based cohort study. Cancer. Oct 1. 2009;115(19):4442-4449. [pmid: 19569248].
223 Bodmer M, Meier C, Krahenbuhl S, et al. Long-term metformin use is associated with decreased risk of breast cancer. Diabetes Care. Jun. 33(6):1304-1308. [pmid: 20299480].
224 5R03CA137777-02. High Content Analysis to Identify Biomarkers for Chemopreventive Drug Activity. 2008.
225 5R01CA129616-03. Chemoprevention by a Targeted Thioredoxin Inhibitor. 2008.
226 NCT00354640. Simvastatin and Anastrozole in Treating Postmenopausal Women With Invasive Breast Cancer, Ductal Carcinoma In Situ, or a High Risk of Breast Cancer.
227 NCT00667121. Tamoxifen in Women With Breast Cancer and in Women at High-Risk of Breast Cancer Who Are Receiving Venlafaxine, Citalopram, Escitalopram, Gabapentin, or Sertraline.
228 NCT00031850. Raloxifene and Goserelin in Preventing Breast Cancer in Women With a Family History of Breast Cancer.
229 NCT00001378. A Pilot Trial of Tamoxifen and 4-HPR (4-N-Hydroxyphenyl Retinamide) in Persons at High Risk for Developing Breast Cancer. 2000.
230 3R01CA118114-03S1. Breast cancer chemoprevention strategies. 2009.
231 5R21CA135237-02. Chemoprevention of Tamoxifen-induced Endometrial Cancer by Black Cohosh and Red C. 2009.
232 Li Z, Carrier L, Belame A, et al. Combination of methylselenocysteine with tamoxifen inhibits MCF-7 breast cancer xenografts in nude mice through elevated apoptosis and reduced angiogenesis. Breast Cancer Research & Treatment. Nov. 2009;118(1):33-43. [pmid: 18855134].
233 5R03CA134199-02. Cigarette Smoking, Alcohol, Obesity, Leisure-time Physical Activity and Quality O. 2008.
234 Vogel VG, Qu Y, Wong M, et al. Incidence of invasive breast cancer in postmenopausal women after discontinuation of long-term raloxifene administration. Clinical breast cancer. Feb. 2009;9(1):45-50. [pmid: 19299240].
235 Neri F, Maggino T. Surveillance of endometrial pathologies, especially for endometrial cancer, of breast cancer patients under tamoxifen treatment. European Journal of Gynaecological Oncology. 2009;30(4):357-360. [pmid: 19761121].
236 NCT01144468. Effects of Exemestane on Bone Strength. 2015.
237 NCT00485953. Effect of Bisphosphonate on Bone Loss in Postmenopausal Women With Breast Cancer Initiating Aromatase Inhibitor Therapy. 2011.
238 NCT00122356. Bisphosphonate and Anastrozole Trial-Bone Maintenance Algorithm Assessment. 2015.
239 NCT00553410. Letrozole in Preventing Cancer in Postmenopausal Women Who Have Received 4–6 Years of Hormone Therapy for Hormone Receptor-Positive, Lymph Node-Positive, Early-Stage Breast Cancer.
240 NCT00002646. Hormone Therapy in Treating Postmenopausal Women With Receptor-Positive Breast Cancer.
241 NCT00004247. Exemestane and Raloxifene in Treating Postmenopausal Women With a History of Ductal Carcinoma in Situ, Stage I, Stage II, or Stage III Breast Cancer.
242 NCT00001837. Effects of Raloxifene on the Uterus and Ovaries of Premenopausal Patients. 2005.
243 NCT00687102. Cognition in the Study of Tamoxifen and Raloxifene. 2008.
244 NCT00026962. Effects of Raloxifene on Hormone Levels. 2003.
245 Archer DF, Pinkerton JV, Utian WH, et al. Bazedoxifene, a selective estrogen receptor modulator: effects on the endometrium, ovaries, and breast from a randomized controlled trial in osteoporotic postmenopausal women. Menopause (New York, N.Y.). Nov–Dec. 2009;16(6):1109-1115.
246 Mosca L, Grady D, Barrett-Connor E, et al. Effect of raloxifene on stroke and venous thromboembolism according to subgroups in postmenopausal women at increased risk of coronary heart disease. Stroke. Jan. 2009;40(1):147-155. [pmid: 18948611].
247 CTRI/2009/091/000625. A Phase I, open label, oral, single-dose, escalating, randomized, parallel study to evaluate safety, tolerability and pharmacokinetics of endoxifen and tamoxifen in healthy adult human male and female subjects under fasting conditions.
248 Falandry C, Debled M, Bachelot T, et al. Celecoxib and exemestane versus placebo and exemestane in postmenopausal metastatic breast cancer patients: a double-blind phase III GINECO study. Breast cancer research and treatment. Aug. 2009;116(3):501-508. [pmid: 19020973].
249 Siesky B, Harris A, Kheradiya N, et al. The effects of raloxifene hydrochloride on ocular hemodynamics and visual function. International Ophthalmology. Aug. 2009;29(4):225-230. [pmid: 18427730].
250 Chung M-T, Cheng P-Y, Lam K-K, et al. Cardioprotective effects of long-term treatment with raloxifene, a selective estrogen receptor modulator, on myocardial ischemia/reperfusion injury in ovariectomized rats. Menopause. Jan–Feb. 2010;17(1):127-134. [pmid: 19745773].
251 Montenegro MF, Pessa LR, Gomes VA, et al. Assessment of vascular effects of tamoxifen and its metabolites on the rat perfused hindquarter vascular bed. Basic & Clinical Pharmacology & Toxicology. May. 2009;104(5):400-407. [pmid: 19413660].
252 Moore CD, Reilly CA, Yost GS. CYP3A4-Mediated oxygenation versus dehydrogenation of raloxifene. Biochemistry. Jun 1. 2010;49(21):4466-4475. [pmid: 20405834].
253 Nishida M, Hasegawa Y, Tanida I, et al. Preventive effects of raloxifene, a selective estrogen receptor modulator, on monocrotaline-induced pulmonary hypertension in intact and ovariectomized female rats. European Journal of Pharmacology. Jul 1. 2009;614(1–3):70-76. [pmid: 19379725].
254 Beca S, Pavlov E, Kargacin ME, et al. Inhibition of a cardiac sarcoplasmic reticulum chloride channel by tamoxifen. Pflugers Archiv-European Journal of Physiology. Oct. 2008;457(1):121-135. [pmid: 18458943].
255 Choi BG, Vilahur G, Zafar MU, et al. Selective estrogen receptor modulation influences atherosclerotic plaque composition in a rabbit menopause model. Atherosclerosis. Nov. 2008;201(1):76-84. [pmid: 18367192].
256 Ikeno A, Minato H, Kohayakawa C, et al. Effect of OS-0544, a selective estrogen receptor modulator, on endothelial function and increased sympathetic activity in ovariectomized rats. Vascular Pharmacology. Jan–Feb;. 2009;50:1-2. 40. 44. [pmid: 18804188].
257 El Gebeily G, Fiset C. 4-Hydroxytamoxifen inhibits K(+) currents in mouse ventricular myocytes. European Journal of Pharmacology. Mar 10. 2010;629(1–3):96-103. [pmid: 20006599].
258 Gibson L, Lawrence D, Dawson C, et al. Aromatase inhibitors for treatment of advanced breast cancer in postmenopausal women. Cochrane Database of Systematic Reviews. 2010;(2).
259 Kazerooni T, Ghaffarpasand F, Mosalaei A, et al. The value of transvaginal ultrasonography in the endometrial evaluation of breast cancer patients using tamoxifen. Medical Principles & Practice. 2010;19(3):222-227. [pmid: 20357508].
260 Leung F, Terzibachian JJ, Govyadovskiy A, et al. [Tamoxifen in the adjuvant setting for breast cancer: Reflexions about the risk of uterine carcinosarcoma]. Gynecologie, Obstetrique & Fertilite. May. 2009;37(5):447-451.
261 Minamitani C, Takai S, Matsushima-Nishiwaki R, et al. Raloxifene-induced acceleration of platelet aggregation. Internal Medicine. 2008;47(17):1523-1528. [pmid: 18758128].
262 Otsuka I, Takahashi S, O’Uchi K, et al. [Clinicopathological features of endometrial carcinoma in tamoxifen-and toremifene-treated breast cancer patients]. Gan to Kagaku Ryoho [Japanese Journal of Cancer & Chemotherapy]. Feb. 2010;37(2):279-283.
263 Qureshi A, Bukhari F, Pervez S. Spectrum of tamoxifen associated endometrial pathology in breast cancer patients. Journal of the Pakistan Medical Association. Apr. 2009;59(4):249-250. [pmid: 19402291].
264 Rapacciuolo A, Carlomagno G, Di Pietro E, et al. Late onset of hypoxemia due to a pulmonary arteriovenous malformation during selective estrogen receptor modulator therapy. Journal of the American College of Cardiology. Feb 2. 2010;55(5):e9. [pmid: 20117453].
265 Reynolds K, Khoury J, Sosnowski J, et al. Comparison of the effect of tamoxifen on endometrial thickness in women with thin endometrium (<7mm) undergoing ovulation induction with clomiphene citrate. Fertility & Sterility. Apr. 2010;93(6):2091-2093. [pmid: 19775686].
266 Sumino H, Ichikawa S. Effects of SERMs on bone health. SERM actions other than on the bones. With special reference to the actions of SERM on the skin and vascular elasticity. Clinical Calcium. Mar. 2010;20(3):388-394. [pmid: 20190369].
267 Sumino H, Ichikawa S, Kasama S, et al. Effects of raloxifene on the renin-angiotensin-aldosterone system and blood pressure in hypertensive and normotensive osteoporotic postmenopausal women. Geriatrics & gerontology international. Jan. 2010;(1):70-77. [pmid: 20102385].
268 Sumino H, Ichikawa S, Kasama S, et al. Effects of raloxifene on brachial arterial endothelial function, carotid wall thickness, and arterial stiffness in osteoporotic postmenopausal women. International Heart Journal. Jan. 2010;51(1):60-67. [pmid: 20145354].
269 Vicus D, Rosen B, Lubinski J, et al. Tamoxifen and the risk of ovarian cancer in BRCA1 mutation carriers. Gynecologic Oncology. Oct. 2009;115(1):135-137. [pmid: 19577280].
270 Guvenal T, Durna A, Erden O, et al. Effects of different postmenopausal hormone therapy regimens on cerebral blood flow and cognitive functions. Advances in therapy. Aug. 2009;26(8):805-811. [pmid: 19672567].
271 Johnston S, Pippen J, Pivot X, et al. Lapatinib combined with letrozole versus letrozole and placebo as first-line therapy for postmenopausal hormone receptor-positive metastatic breast cancer. Journal of clinical oncology : official journal of the American Society of Clinical Oncology. Nov. 2009;27(33):5538-5546. [pmid: 19786658].
272 Pinkerton JV, Archer DF, Utian WH, et al. Bazedoxifene effects on the reproductive tract in postmenopausal women at risk for osteoporosis. Menopause (New York, N.Y.). Nov–Dec. 2009;16(6):1102-1108.
273 Schaefers M, Muysers C, Alexandersen P, et al. Effect of microdose transdermal 17beta-estradiol compared with raloxifene in the prevention of bone loss in healthy postmenopausal women: a 2-year, randomized, double-blind trial. Menopause (New York, N.Y.). May–Jun. 2009;16(3):559-565.
274 Sontag A, Wan X, Krege JH. Benefits and risks of raloxifene by vertebral fracture status. Current medical research and opinion. Jan. 2010;26(1):71-76. [pmid: 19908937].
275 Ajit D, Gavas S, Jagtap S, et al. Cytodiagnostic problems in cervicovaginal smears from symptomatic breast cancer patients on tamoxifen therapy. Acta Cytologica. Jul–Aug. 2009;53(4):383-388. [pmid: 19697721].
276 Ashraf M, Biswas J, Majumdar S, et al. Tamoxifen use in Indian women—adverse effects revisited. Asian Pacific Journal of Cancer Prevention. Oct–Dec. 2009;10(4):609-612. [pmid: 19827879].
277 Barrett-Connor E, Cox DA, Song J, et al. Raloxifene and risk for stroke based on the framingham stroke risk score. American Journal of Medicine. Aug. 2009;122(8):754-761. [pmid: 19540454].
278 Behtash N, Hashemi R, Karimi Zarchi M. Uterine malignancy following tamoxifen use in breast cancer patients in Iran: case series and literature review. Asian Pacific Journal of Cancer Prevention. Jan–Mar. 2009;10(1):163-166. [pmid: 19469647].
279 Bertelli G, Hall E, Ireland E, et al. Long-term endometrial effects in postmenopausal women with early breast cancer participating in the Intergroup Exemestane Study (IES) —a randomised controlled trial of exemestane versus continued tamoxifen after 2–3 years tamoxifen. Annals of Oncology. Mar. 2010;21(3):498-505. [pmid: 19717534].
280 Bland AE, Calingaert B, Secord AA, et al. Relationship between tamoxifen use and high risk endometrial cancer histologic types. Gynecologic Oncology. Jan. 2009;112(1):150-154. [pmid: 18937966].
281 Bruce D, Frick A, Rymer J, et al. A comparison of hormone therapies on the urinary excretion of prostacyclin and thromboxane A2. Climacteric. 2008;11(6):447-453. [pmid: 18821092].
282 Candelaria M, Hurtado-Monroy R, Vargas-Viveros P, et al. Tamoxifen-associated vasculitis in a breast cancer patient. World Journal of Surgical Oncology. 2007;5:9. [pmid: 17244373].
283 Chan YC, Leung FP, Wong WT, et al. Therapeutically relevant concentrations of raloxifene dilate pressurized rat resistance arteries via calcium-dependent endothelial nitric oxide synthase activation. Arteriosclerosis, Thrombosis & Vascular Biology. May. 2010;30(5):992-999.
284 Collins P, Mosca L, Geiger MJ, et al. Effects of the selective estrogen receptor modulator raloxifene on coronary outcomes in the Raloxifene Use for The Heart trial: results of subgroup analyses by age and other factors. Circulation. Feb 24. 2009;119(7):922-930. [pmid: 19204301].
285 Grimes C, Lalude O. Unusual case of a sigmoid mass. Journal of Gastrointestinal Cancer. Mar. 2010;41(1):6-8. [pmid: 19960277].
286 Ewer MS, Gluck S. A woman’s heart: the impact of adjuvant endocrine therapy on cardiovascular health. Cancer. May 1. 2009;115(9):1813-1826. [pmid: 19235248].
287 Duygu H, Akman L, Ozerkan F, et al. Comparison of the effects of new and conventional hormone replacement therapies on left ventricular diastolic function in healthy postmenopausal women: a Doppler and ultrasonic backscatter study. The international journal of cardiovascular imaging. Apr. 2009;25(4):387-396. [pmid: 19194783].
288 Dibi RP, Zettler CG, Pessini SA, et al. Tamoxifen use and endometrial lesions: hysteroscopic, histological, and immunohistochemical findings in postmenopausal women with breast cancer. Menopause. Mar–Apr. 2009;16(2):293-300. [pmid: 19034048].
289 Dogan S, Plantinga Y, Evans GW, et al. Ultrasound protocols to measure carotid intima-media thickness: a post-hoc analysis of the OPAL study. Current Medical Research & Opinion. Jan. 2009;25(1):109-122. [pmid: 19210144].
290 Legault C, Maki PM, Resnick SM, et al. Effects of tamoxifen and raloxifene on memory and other cognitive abilities: cognition in the study of tamoxifen and raloxifene. Journal of clinical oncology : official journal of the American Society of Clinical Oncology. Nov. 2009;27(31):5144-5152. [pmid: 19770382].
291 Altschuler A, Somkin CP. Women’s decision making about whether or not to use breast cancer chemoprevention. Women Health. 2005;41(2):81-95. [pmid: 16219589].
292 Cyrus-David MS, Strom SS. Chemoprevention of breast cancer with selective estrogen receptor modulators: views from broadly diverse focus groups of women with elevated risk for breast cancer. Psychooncology. Nov–Dec. 2001;10(6):521-533. [pmid: 11747064].
293 Cyrus-David M, King J, Bevers T, et al. Validity assessment of the Breast Cancer Risk Reduction Health Belief scale. Cancer. Nov 1. 2009;115(21):4907-4916. [pmid: 19637346].
294 Heisey R, Pimlott N, Clemons M, et al. Women’s views on chemoprevention of breast cancer: qualitative study. Canadian Family Physician. May. 2006;52:624-625. [pmid: 17327893].
295 Kaplan CP, Haas JS, Perez-Stable EJ, et al. Breast cancer risk reduction options: awareness, discussion, and use among women from four ethnic groups. Cancer Epidemiology, Biomarkers & Prevention. Jan. 2006;15(1):162-166.
296 Morgan D, Sylvester H, Lucas FL, et al. Cancer prevention and screening practices among women at risk for hereditary breast and ovarian cancer after genetic counseling in the community setting. Familial Cancer. 2009;8(4):277-287. [pmid: 19347608].
297 Metcalfe KA, Snyder C, Seidel J, et al. The use of preventive measures among healthy women who carry a BRCA1 or BRCA2 mutation. Familial Cancer. 2005;4(2):97-103. [pmid: 15951959].
298 Tjia J, Micco E, Armstrong K. Interest in breast cancer chemoprevention among older women. Breast Cancer Research & Treatment. Apr. 2008;108(3):435-453. [pmid: 17554628].
299 Buchanan AH, Skinner CS, Rawl SM, et al. Patients’ interest in discussing cancer risk and risk management with primary care physicians. Patient Education & Counseling. Apr. 2005;57(1):77-87. [pmid: 15797155].
300 Fasching PA, von Minckwitz G, Fischer T, et al. The impact of breast cancer awareness and socioeconomic status on willingness to receive breast cancer prevention drugs. Breast Cancer Research & Treatment. Jan. 2007;101(1):95-104. [pmid: 17033928].
301 Hembroff LA, Holmes-Rovner M, Wills CE. Treatment decision-making and the form of risk communication: results of a factorial survey. BMC Med Inform Decis Mak. Nov 16. 2004;4:20. [pmid: 15546488].
302 Loehberg CR, Jud SM, Haeberle L, et al. Breast cancer risk assessment in a mammography screening program and participation in the IBIS-II chemoprevention trial. Breast Cancer Research & Treatment. May. 2010;121(1):101-110. [pmid: 20306293].
303 NCT00347568. BC-DAISY: A Breast Cancer Decision Aid System. 2009.
304 5R21NR009868-02. Facilitating Web-based Patient Decision Support for Hereditary Breast Cancer Risk. 2008.
305 Fagerlin A, Zikmund-Fisher BJ, Nair V, et al. Women’s decisions regarding tamoxifen for breast cancer prevention: responses to a tailored decision aid. Breast Cancer Research & Treatment. Feb. 2010;119(3):613-620. [pmid: 19908143].
306 Ozanne EM, Annis C, Adduci K, et al. Pilot trial of a computerized decision aid for breast cancer prevention. Breast Journal. Mar–Apr. 2007;13(2):147-154. [pmid: 17319855].
307 NCT00597454. An Access Delivery Model That Eliminates Barriers to Breast Cancer Care Delivery. 2010.
308 NCT00379782. Kukui Ahi Navigator Cancer Screening and Treatment Demonstration Project. 2010.
309 NCT00453661. Cancer Prevention and Treatment Demonstration for Ethnic and Racial Minorities.
310 NCT00477646. Helping Women Stay Up-To-Date With Cancer Screening By Using a Prevention Care Manager or Usual Care.
311 NCT01027741. Integrating Cancer Control Referrals and Navigators Into United Way 211 Missouri. 2011.
312 Matloff ET, Moyer A, Shannon KM, et al. Healthy women with a family history of breast cancer: impact of a tailored genetic counseling intervention on risk perception, knowledge, and menopausal therapy decision making. Journal of Women’s Health. Sep. 2006;15(7):843-856.
313 Maurice A, Howell A, Evans DG, et al. Predicting compliance in a breast cancer prevention trial. Breast Journal. Sep–Oct. 2006;12(5):446-450. [pmid: 16958964].
314 Tchou J, Hou N, Rademaker A, et al. Acceptance of tamoxifen chemoprevention by physicians and women at risk. Cancer. May 1. 2004;100(9):1800-1806. [pmid: 15112259].
315 Yen TW, Hunt KK, Mirza NQ, et al. Physician recommendations regarding tamoxifen and patient utilization of tamoxifen after surgery for ductal carcinoma in situ. Cancer. Mar 1. 2004;100(5):942-949. [pmid: 14983489].
316 Maisonneuve AS, Huiart L, Rabayrol L, et al. Acceptability of cancer chemoprevention trials: impact of the design. Int J Med Sci. 2008;5(5):244-247. [pmid: 18769562].
317 Meiser B, Butow P, Price M, et al. Attitudes to prophylactic surgery and chemoprevention in Australian women at increased risk for breast cancer. Journal of Women’s Health. Oct. 2003;12(8):769-778.
318 Nguyen TT, Somkin CP, Ma Y. Participation of Asian-American women in cancer chemoprevention research: physician perspectives. Cancer. Dec 15. 2005;104(12 Suppl):3006-3014. [pmid: 16247807].
319 Armstrong K, Quistberg DA, Micco E, et al. Prescription of tamoxifen for breast cancer prevention by primary care physicians. Arch Intern Med. Nov 13. 2006;166(20):2260-2265. [pmid: 17101945].
320 Guerra CE, Sherman M, Armstrong K. Diffusion of breast cancer risk assessment in primary care. J Am Board Fam Med. May–Jun. 2009;22(3):272-279. [pmid: 19429733].
321 Battaglia TA, Ash A, Prout MN, et al. Cancer prevention trials and primary care physicians: factors associated with recommending trial enrollment. Cancer Detection & Prevention. 2006;30(1):34-37. [pmid: 16476525].
322 Coyle D, Wells G, Graham I, et al. The impact of risk on preference values: implications for evaluations of postmenopausal osteoporosis therapy. Value Health. Sep–Oct. 2001;4(5):385-391. [pmid: 11705129].
323 Melnikow J, Paterniti D, Azari R, et al. Preferences of Women Evaluating Risks of Tamoxifen (POWER) study of preferences for tamoxifen for breast cancer risk reduction. Cancer. May 15. 2005;103(10):1996-2005. [pmid: 15825209].
324 Haas JS, Kaplan CP, Gregorich SE, et al. Do physicians tailor their recommendations for breast cancer risk reduction based on patient’s risk?. J Gen Intern Med. Apr. 2004;19(4):302-309. [pmid: 15061738].
325 Skinner CS, Rawl SM, Moser BK, et al. Impact of the Cancer Risk Intake System on patient-clinician discussions of tamoxifen, genetic counseling, and colonoscopy. Journal of General Internal Medicine. Apr. 2005;20(4):360-365. [pmid: 15857495].
326 Snyder LA, Soballe DB, Lahl LL, et al. Development of the breast cancer education and risk assessment program. Oncology Nursing Forum. Sep–Oct. 2003;30(5):803-808. [pmid: 12949593].
327 Zikmund-Fisher BJ, Ubel PA, Smith DM, et al. Communicating side effect risks in a tamoxifen prophylaxis decision aid: the debiasing influence of pictographs. Patient Education & Counseling. Nov. 2008;73(2):209-214. [pmid: 18602242].
328 NCT00469339. Risk Communication Within Mexican-American Families. 2009.
329 NCT00742755. Increasing Adherence to Follow-up of Breast Abnormalities in Low-Income Korean American Women. 2009.
330 NCT00150917. RCT of a Group Intervention for Women With a Family History of Breast Cancer. 2007.
331 Liebens F, Aimont M, Beauraing F, et al. What information do public organizations provide to Belgian women on primary prevention of breast cancer?. European Journal of Cancer Prevention. Jan. 2010;19(1):68-70. [pmid: 19955905].
332 1R21CA141097-01A1. Evaluating a Decision Aid for Breat Cancer Prevention: A Pilot Trial. 2010.
333 IOM (Institute of Medicine). Initial National Priorities for Comparative Effectiveness Research. Washington DC. The National Academies Press. 2009.