# Executive Summary

The Effective Health Care Program was initiated in 2005 to provide valid evidence about the comparative effectiveness of different medical interventions. The object is to help consumers, health care providers, and others in making informed choices among treatment alternatives. Through its comparative effectiveness reviews, the program supports systematic appraisals of existing scientific evidence regarding treatments for high-priority health conditions. It also promotes and generates new scientific evidence by identifying gaps in existing scientific evidence and supporting new research. The program puts special emphasis on translating findings into a variety of useful formats for different stakeholders, including consumers.

The full report and this summary are available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.

## Background

Breast cancer is the second most commonly diagnosed cancer and the second most common cause of cancer-related death in women with more than 200,000 new cases of invasive breast cancer expected in women in 2010 and more than 40,000 breast cancer-related deaths expected this year in the United States.1 Despite U.S. Food and Drug Administration (FDA) approval and clinical endorsement for the use of selective estrogen receptor modulators (SERMs) to reduce the risk of breast cancer, less than 1 percent of U.S. women use tamoxifen citrate as preventive therapy.2,3,4 The 2009 comparative effectiveness review (CER) on the effectiveness of medications to reduce the risk of primary breast cancer in women without preexisting cancer demonstrated the efficacy of two SERMs, tamoxifen citrate (RR, 0.70; 95% CI, 0.59 to 0.82; 4 trials) and raloxifene (RR, 0.44; CI, 0.27 to 0.71; 2 trials).5,6 However, the CER also outlined many adverse effects and unknowns about the medications. The objective of this pilot project was to engage stakeholders to develop and prioritize a list of research questions to address the research gaps related to the CER. First, our goal was to provide sufficient detail—including population, intervention, comparator, and outcome (PICO)—for researchers and funders to use in the development of research proposals and solicitations, respectively.7 Second, this project was intended to identify a feasible and effective approach to identify and prioritize future research from systematic reviews in general.

## Methods

A diverse group of stakeholders were selected to include clinicians, consumer advocates, research funders, researchers, and policymakers were invited to participate in a project to develop a research agenda to reduce the risk of primary breast cancer. Recruitment of stakeholders began June 11 and final questionnaire responses were received July 27, 2010.

Stakeholders were invited to participate in an informational Webinar and to complete a research prioritization questionnaire. Two questionnaires were developed to evaluate the research priorities for breast cancer prevention: one for consumers/policymakers (Questionnaire I) and another for clinicians, research funders, and researchers (Questionnaire II). The questionnaires were constructed from information gaps identified in the CER, through informational interviews with the lead investigator for the CER, and through informational interviews with basic science and clinical researchers. The questionnaire used open-ended and structured questions to identify high priority research topics.

Narrative responses were categorized according to questionnaire. Four investigators independently reviewed responses and narratives, identified research themes, and coded each theme as population, intervention, comparator, outcome, and influencing factors (PICO). Investigators met to compare codes and themes and reconciled inconsistencies. The top 10 research priorities (see Table A) were then listed and compared by questionnaire type.

Table A Top 10 priority research areas to reduce the risk of primary breast cancer

Questionnaire I: Consumer/Policymaker | % High Priority^a^ | Rank | Questionnaire II: Clinician/Research Funder/Researcher | % High Priority^a^ | Rank
Persistent effect of preventive therapy | 100% | 1 | How to communicate benefits and risks to patients | 83.3% | 1
Reporting harmful effects of preventive therapy | 88.9% | 2 | Predicting risk of breast cancer | 75.0% | 2
Predicting risk of breast cancer | 88.9% | 2 | Understanding which populations of women would optimally benefit from medications to reduce the risk of breast cancer | 75.0% | 2
Studies of how to communicate benefits and risks to patients | 77.8% | 4 | How clinicians are weighing the risks and benefits to preventive therapy | 75.0% | 2
Studies of what populations optimally benefit from medications to reduce the risk of breast cancer | 77.8% | 4 | Persistent effect of preventive therapy | 66.7% | 5
Complementary and alternative therapies | 66.7% | 6 | Patient attitudes toward prescribing medications to reduce breast cancer risk | 66.7% | 5
Studies of how race and/or ethnicity affect interventions to reduce the risk of breast cancer | 66.7% | 6 | Studies of clinicians’ attitudes toward prescribing medications | 58.3% | 7
Molecular targeted drugs specific to cancer pathways | 62.5% | 8 | Aromatase Inhibitors | 54.5% | 8
What factors influence a woman’s decisionmaking to take medications to reduce breast cancer risk | 55.6% | 9 | SERMs | 54.5% | 8
SERMs | 50.0% | 10 | Gene-based drugs | 54.5% | 8
Combination therapies: i.e., prescription medications plus diet | 50.0% | 10

Abbreviations: SERM=selective estrogen receptor modulator.

a Percentages indicate a priority ranking of “high” by respondents from choices of “high,” “medium,” or “low.”

## Results

Twenty-one of 40 (53%) invited stakeholders completed the questionnaire. Nine consumers and policymakers completed Questionnaire I, and 12 clinicians, research funders (including 3 federal employees) and researchers completed Questionnaire II. Based on the answers to open-ended questions, stakeholders agreed that a priority for future research should be placed on understanding which populations are at greatest risk for breast cancer and those most likely to benefit from preventive therapies. However, while consumers and policymakers focused on demographic factors, such as age, race, and ethnicity of the population, clinicians, research funders, and researchers focused on examining risk based on genetics and biomarkers. As a whole, stakeholders were highly interested in nonmedical interventions, such as lifestyle changes, diet, and exercise, while clinicians, research funders, and researchers wanted not only more information on the effectiveness of individual lifestyle changes but also direct comparisons of medical vs. nonmedical treatments. Similarly, stakeholders agreed that research is needed to identify and evaluate methods to ensure that health care providers were up to date in their knowledge and to promote informed decisionmaking. Compared with researchers, clinicians, and funders, consumers, and policymakers were more likely to want additional research on patient–provider communication and how to communicate risks to patients.

Looking across all structured questions, at least 50 percent of respondents in both Questionnaire I and Questionnaire II groups (consumer/policymaker and researcher/research funder/clinician, respectively) rated the following five questions as highest priority by PICO:

Population: | Studies of how age affects the benefits and/or harms of interventions to reduce the risk of breast cancer (78%; 75%)
Intervention: | Prescription medications: tamoxifen, raloxifene (50%; 55%)
Outcome: | Evaluation of how long the beneficial effects of therapy last (100%; 67%)
Influencing Factors: | Studies of how to communicate benefits and risk to patients (78%; 83%) and Research on predicting risk of breast cancer (89%; 75%)

Additionally, 100 percent of consumers, policymakers, research funders, researchers, and clinicians reported that patients would use a prediction model to assist in their decisionmaking if a current model were available.

The table below summarizes the top 10 priority research areas by highest rank, grouped according to questionnaire type.

## Conclusions

We developed a conceptual framework to illustrate national priorities for future research to reduce the risk of primary breast cancer in women (see Figure A).

Figure A Conceptual framework, future research needs to reduce the risk of primary breast cancer

This flowchart depicts an enhanced conceptual framework to illustrate priorities for future research to reduce the risk of primary breast cancer in women. The chart emphasizes high priority research domains and depicts “influencing factors” important to stakeholders and integral to patient-centered care: health system/organization, social, educational, economic, and environmental factors. A series of research questions are applied to these high priority research domains, with the overall goal of understanding which interventions are most effective to reduce risk of breast cancer for which patients under what circumstances.

According to stakeholders, the highest priority research areas for the prevention of breast cancer are:

1. Population—understanding which populations are at highest risk of breast cancer, most likely to experience benefit, and least likely to be harmed by therapy (Question A).
2. Intervention—broadening the scope of investigation beyond medications to include factors such as lifestyle, diet and exercise (Question B).
3. Influencing factors—understanding influences such as health system factors, communication, education, dissemination of high quality information into clinical practice and to patients, and decisionmaking on initiation, continuation, and responses to preventive therapies (Question C).
4. Integration of biological markers across the spectrum of research relating to breast cancer to understand populations that are most likely to benefit from therapy and to monitor response to therapy (integrated in Questions A, B, and C).

Because two of these priority topic areas, interventions extending beyond medications (Question B) and influencing factors (Question C), were largely outside the scope of the original CER, an evidence review could help delineate what is known and guide research in these areas. Preliminary searches indicate there is likely to be a sufficient literature for both. Potential study designs to address Question A could include the use of registries and/or large cohorts such as the Women’s Health Initiative or the Nurses’ Health Studies I and II to identify predictors for breast cancer risk. Longer followup of existing intervention studies would be very helpful to identify the women who are most likely to have sustained benefit.

We found that the traditional analytic framework used to structure reviews does not adequately address future research needs. We present a conceptual framework for future research that emphasizes high priority research domains and depicts “influencing factors” that are important to stakeholders and integral to patient-centered care.8,9,10 The prominence of influencing factors among stakeholder priorities suggests that they should be depicted in CER frameworks and added to PICO as I PICO.

## Executive Summary References

1 Cancer Facts & Figures. 2010. Available at http://www.cancer.org/acs/groups/content/@nho/documents/document/acspc-024113.pdf.
2 Freedman AN, Graubard BI, Rao SR, et al. Estimates of the number of US women who could benefit from tamoxifen for breast cancer chemoprevention. J Natl Cancer Inst. Apr 2. 2003;95(7):526-532. [pmid: 12671020].
3 Waters EA, Cronin KA, Graubard BI, et al. Prevalence of tamoxifen use for breast cancer chemoprevention among U.S. women. Cancer Epidemiology, Biomarkers & Prevention. Feb. 2010;19(2):443-446.
4 FDA Approval for Raloxifene Hydrochloride. Available at http://www.cancer.gov/cancertopics/druginfo/fda-raloxifene-hydrochloride.
5 Nelson H, Fu R, Griffin J, et al. Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer. Ann Intern Med. 2009;151(10):703-715. [pmid: 19920271].
6 Nelson H, Fu R, Humphrey L, et al. Comparative effectiveness of medications to reduce risk of primary breast cancer in women, Comparative Effectiveness Review No 17. Rockville, MD. Agency for Healthcare Research and Quality. 2009.
7 Brown P, Brunnhuber K, Chalkidou K, et al. How to formulate research recommendations. British Medical Journal. Oct 14. 2006;333(7572):804-806. [pmid: 17038740].
8 Guise J-M, Denman M, Emeis C, et al. Vaginal birth after cesarean: new insights on maternal and neonatal outcomes. Obstet Gynecol. Jun. 2010;115(6):112-113.
9 Guise J-M, Eden K, Emeis C, et al. Vaginal Birth After Cesarean: New Insights, Evidence Report/Technology Assessment No. 191. (Prepared by the Oregon Health & Science University Evidence-based Practice Center under Contract No. 290-2007-10057-I). March. 2010.
10 Whitlock E, Orleans C, Pender N, et al. Evaluating primary care behavioral counseling interventions: An evidence-based approach. Am J Prev Med. 2002;22(4):267-284. [pmid: 11988383].